# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-diphenylhydrazine in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs which are substance specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-diphenylhydrazine.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Diphenylhydrazine

Agency | Description | Information | Reference
Air
EPA | RfC | Value not derived | IRIS 2006
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | Not assessed | IRIS 2006
WHO | Drinking water quality guidelines | Not listed | WHO 2017
FDA | Substances Added to Food | Not listed^a^ | FDA 2020
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2016
EPA | Carcinogenicity classification | B2^b^ | IRIS 2006
IARC | Carcinogenicity classification | Not listed | IARC 2020
Occupational
ACGIH | TLV (TWA) | Not listed | ACGIH 2019
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | Not listed | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | Not listed | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^c^ | 120 mg/m^3^ | DOE 2018a
DOE | PAC-2^c^ | 1,300 mg/m^3^ | DOE 2018a
DOE | PAC-3^c^ | 7,900 mg/m^3^ | DOE 2018a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b B2: probable human carcinogen.

c Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization