# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,2-diphenylhydrazine listed in Table 4-1.

Table 4-1 Chemical Identity of 1,2-Diphenylhydrazine

Characteristic | Information
Chemical name | 1,2-Diphenylhydrazine
Synonym(s) and registered trade name(s) | Hydrazobenzene; N,N’-diphenylhydrazine; sym-diphenylhydrazine
Chemical formula | C_12_H_12_N_12_
Chemical structure | Chemical structure for 1,2-Diphenylhydrazine
Identification numbers:
CAS Registry | 122-66-7

Source: NLM 2020

CAS = Chemical Abstracts Services

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,2-diphenylhydrazine are presented in Table 4-2. 1,2-Diphenylhydrazine can rapidly oxidize to azobenzene under some environmental conditions; therefore, accurate experimental determination of properties such as the water solubility and Henry’s Law constant may not be possible.

Table 4-2 Physical and Chemical Properties of 1,2-Diphenylhydrazine

Property | Information | Reference
Molecular weight | 184.24
Color | White | Ahuja et al. 1989
Physical state | Crystalline solid | Dean 1985
Melting point | 123–126°C | NLM 2020
Boiling point | 309°C | NLM 2020
Density at 20°C
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C^a^ | 66.9 mg/L (estimated) | NLM 2020
Organic solvents | Very soluble in alcohol; slightly soluble in benzene | Dean 1985
Partition coefficients:
Log K_ow_ | 2.94 (experimental) | Hansch et al. 1995
Log K_oc_ | 2.73 (calculated using equation 4–10) | Lyman et al. 1982
Vapor pressure at 25°C | 2.6x10^-5^ mmHg | EPA 1982a
Henry’s law constant at 25°C^a^ | 9.42x10^-8^ atm-m^3^/mol (estimated)
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | No data