# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR 1,2-DIPHENYLHYDRAZINE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to 1,2-diphenylhydrazine, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to 1,2-diphenylhydrazine:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 1,2-diphenylhydrazine. The inclusion criteria used to identify relevant studies examining the health effects of 1,2-diphenylhydrazine are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of 1,2-diphenylhydrazine. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

Table C-1 Inclusion Criteria for Identifying Health Effect Studies

- Species; - Human; - Laboratory mammals
- Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
- Health outcome
- - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for 1,2-diphenylhydrazine released for public comment in 2019. See Appendix B for the databases searched and the search strategy.

A total of 27 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of 1,2-diphenylhydrazine.

Title and Abstract Screen. In the Title and Abstract Screen step, 27 records were reviewed; 0 documents were considered to meet the health effects inclusion criteria in Table B-1.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 7 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 7 documents, 13 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for 1,2-Diphenylhydrazine and overviews of the results of the oral and dermal exposure studies (no inhalation exposure studies were identified) are presented in Sections 2.2–2.18 of the profile and oral data are summarized in the Levels Significant Exposures table in Section 2.1 of the profile (Table 2-1).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for 1,2-diphenylhydrazine identified in animal studies (no human studies were identified) are presented in Table C-3. Animal studies examined a number of endpoints following oral exposure (dermal study only examined cancer endpoints). These studies examined most endpoints and reported respiratory, gastrointestinal, and hepatic effects. Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 13 studies (published in 7 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for 1,2-Diphenylhydrazine Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration
Oral studies
Acute-duration | 2 | 0 | | 0 | | | 2
Acute-duration | 0 | 0 | | 0 | | | 0
Intermediate-duration | 5 | | | 1 | | | 2
Intermediate-duration | 0 | | | 1 | | | 1
Chronic-duration | 2 | 2 | 2 | 2 | | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | | 2
Chronic-duration | 2 | 2 | 0 | 0 | | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | | 2
Dermal studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration | | | | | | | | | | | | | | | | | 1
Chronic-duration | | | | | | | | | | | | | | | | | 1
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for animal experimental studies are presented in Table C-4. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-4 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of 1,2-diphenylhydrazine health effects studies in animal experimental studies are presented in Table C-5.

Table C-5 Summary of Risk of Bias Assessment for 1,2-Diphenylhydrazine—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in exposure characterization? | Confidence in outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Respiratory Effects
Oral chronic exposure
NCI 1978 (rat) | + | + | + | + | ++ | + | + | + | First
NCI 1978 (mouse) | + | + | + | + | ++ | + | + | + | First
Outcome: Gastrointestinal Effects
Oral intermediate exposure
NCI 1978 (mouse, 4-week) | + | + | + | + | + | − | + | − | First
Oral chronic exposure
NCI 1978 (rat) | + | + | + | + | ++ | + | + | + | First
NCI 1978 (mouse) | + | + | + | + | ++ | + | + | + | First
Outcome: Hepatic Effects
Oral acute exposure
Dodd et al. 2012 (5-day) | ++ | + | + | + | ++ | + | + | ++ | First
Dodd et al. 2012 (2-week) | ++ | + | + | + | ++ | + | + | ++ | First
Oral intermediate exposure
Dodd et al. 2012 (4-week) | ++ | + | + | + | ++ | + | + | ++ | First
Dodd et al. 2012 (13-week) | ++ | + | + | + | ++ | + | + | ++ | First
Oral chronic exposure
NCI 1978 (rat) | + | + | + | + | ++ | + | + | + | First
NCI 1978 (mouse) | + | + | + | + | ++ | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to 1,2-diphenylhydrazine and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to 1,2-diphenylhydrazine and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for experimental animal studies are presented in Table C-6. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-6 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining body weight, respiratory, gastrointestinal, and hepatic effects observed in the animal experimental studies are presented in Table C-7.

Table C-7 Presence of Key Features of Study Design for 1,2-Diphenylhydrazine—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory Effects
Oral chronic exposure
NCI 1978 (rat) | Yes | Yes | No | Yes | Moderate
NCI 1978 (mouse) | Yes | Yes | No | Yes | Moderate
Outcome: Gastrointestinal Effects
Oral intermediate exposure
NCI 1978 (mouse, 4-week) | Yes | No | No | No | Very Low
Oral chronic exposure
NCI 1978 (rat) | Yes | Yes | No | Yes | Moderate
NCI 1978 (mouse) | Yes | Yes | No | Yes | Moderate
Outcome: Hepatic Effects
Oral acute exposure
Dodd et al. 2012 (5-day) | Yes | Yes | Yes | Yes | High
Dodd et al. 2012 (2-week) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Dodd et al. 2012 (4-week) | Yes | Yes | Yes | Yes | High
Dodd et al. 2012 (13-week) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NCI 1978 (rat) | Yes | Yes | No | Yes | Moderate
NCI 1978 (mouse) | Yes | Yes | No | Yes | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-8. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-8.

Table C-8 Initial Confidence Rating for 1,2-Diphenylhydrazine Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory Effects
Oral chronic exposure
Animal studies
NCI 1978 (rat) | Moderate | Moderate
NCI 1978 (mouse) | Moderate | Moderate
Outcome: Gastrointestinal Effects
Oral intermediate exposure
Animal studies
NCI 1978 (mouse, 4-week) | Very Low | Very Low
Oral chronic exposure
Animal studies
NCI 1978 (rat) | Moderate | Moderate
NCI 1978 (mouse) | Moderate | Moderate
Outcome: Hepatic Effects
Oral acute exposure
Animal studies
Dodd et al. 2012 (5-day) | High | High
Dodd et al. 2012 (2-week) | High | High
Oral intermediate exposure
Animal studies
Dodd et al. 2012 (4-week) | High | High
Dodd et al. 2012 (13-week) | High | High
Oral chronic exposure
Animal studies
NCI 1978 (rat) | Moderate | Moderate
NCI 1978 (mouse) | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for body weight, respiratory, gastrointestinal, and hepatic effects are presented in Table C-9. An overview of the confidence in the body of evidence for all health effects associated with 1,2-diphenylhydrazine exposure is presented in Table C-10.

Table C-9 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory Effects
Animal studies | Moderate | −1 inconsistency, −1 imprecision | Very Low
Outcome: Gastrointestinal Effects
Animal studies | Moderate | -1 inconsistency | Low
Outcome: Hepatic Effects
Animal studies | High | No adjustments | High

Table C-10 Confidence in the Body of Evidence for 1,2-Diphenylhydrazine

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | No data | Very Low
Gastrointestinal effects | No data | Low
Hepatic effects | No data | High

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Table C-5). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for 1,2-diphenylhydrazine, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for 1,2-diphenylhydrazine is presented in Table C-11.

Table C-11 Level of Evidence of Health Effects for 1,2-Diphenylhydrazine

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects | No data | | No data
Gastrointestinal effects | No data | | No data
Hepatic effects | No data | | No data
Animal studies
Respiratory effects | Very Low | Health effect | Inadequate
Gastrointestinal effects | Low | Health effect | Low
Hepatic effects | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for 1,2-diphenylhydrazine are listed below and summarized in Table C-12.

Presumed Health Effects

- Hepatic effects
  ○ No human data are available on the potential hepatic effects of 1,2-diphenylhydrazine.
  ○ High level of evidence from intermediate (Dodd et al. 2012) and chronic (NCI 1978) oral studies in rats and chronic oral studies in mice (NCI 1978). No liver effects were observed at exposures of less than 13 weeks in rats (Dodd et al. 2012; NCI 1978) or mice (NCI 1978).

Not Classifiable Effects

- Respiratory effects
  ○ No human data are available on the potential respiratory effects of 1,2-diphenylhydrazine.
  ○ There is inadequate evidence in animal studies that chronic oral exposure will result in respiratory effects. Interstitial lung inflammation was observed in male rats (NCI 1978); in female rats the incidence was not dose-related. Respiratory effects were not observed in mice following chronic oral exposure (NCI 1978).
- Gastrointestinal effects
  ○ No human data are available on the potential gastrointestinal effects of 1,2-diphenylhydrazine.
  ○ Low evidence in animals from an intermediate oral study which reported intestinal hemorrhage in mice (NCI 1978) and from a chronic oral study in rats that reported hyperkeratosis and/or acanthosis in rats (NCI 1978); no gastrointestinal effects were observed in mice following chronic oral exposure.

Table C-12 Hazard Identification Conclusions for 1,2-Diphenylhydrazine

Outcome | Hazard identification
Respiratory effects | Not classifiable
Gastrointestinal effects | Not classifiable
Hepatic effects | Presumed

Figure C-1 Hazard Identification Scheme

Figure C-1 description