# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were identified for 1,2-diphenylhydrazine.

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified for 1,2-diphenylhydrazine.

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for 1,2-diphenylhydrazine.

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The acute-duration oral database was not considered suitable for derivation of an MRL because lethality was the only adverse effect observed in the available studies.

The Dodd et al. (2012) study of 1,2-diphenylhydrazine is the only acute oral toxicity study that evaluated endpoints other than lethality. The study found no adverse alterations in body weight, liver weight, liver enzymes, or liver histopathology in rats treated with 1,2-diphenyhydrazine for 5 days or 2 weeks at doses as high as 15.5 mg/kg/day.

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.05 mg/kg/day
Critical Effect: | Hepatic effects
Reference: | Dodd et al. 2012
Point of Departure: | NOAEL of 4.8 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 6
Species: | Rat

MRL Summary: An intermediate oral MRL of 0.05 mg/kg/day was derived for 1,2-diphenylhydrazine. The MRL is based on a NOAEL of 4.80 mg/kg/day for hepatic effects in rats exposed to 1,2-diphenylhydrazaine in the diet for 13 weeks (Dodd et al. 2012). This NOAEL was divided by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 to account for intra-human variation).

Selection of the Critical Effect: Three studies have evaluated toxicity of 1,2-diphenyhydrazine following intermediate-duration oral exposure. Effects identified include death, gastrointestinal effects, and hepatic effects (Dodd et al. 2012; Marhold et al. 1968; NCI 1978). Increases in mortality were observed in rats at 54 mg/kg/day (NCI 1978) and in mice exposed to 390 mg/kg/day (NCI 1978). An increase in intestinal hemorrhage was reported in mice exposed to 390 mg/kg/day for 4 weeks (NCI 1978); gastrointestinal effects were not observed in similarly exposed rats. Dodd et al. (2012) reported significant increases in the incidences of hypertrophy, eosinophilic granular cytoplasm, and bile duct duplication in the livers of rats exposed to ≥10.3 mg/kg/day for 13 weeks, but not after 4 weeks of exposure. At 15.5 mg/kg/day, macrovesiculation was also observed in the liver of rats exposed for 13 weeks (Dodd et al. 2012). No other intermediate-duration studies included histological examination of the liver. Based on the limited available data, the liver appears to be the most sensitive target of toxicity. This is supported by liver effects (fatty metamorphosis or coagulative necrosis) in rats and mice chronically exposed to 1,2-diphenylhydrazine in the diet (NCI 1978).

Selection of the Principal Study: Due to incomplete details of study design and lack of histopathology data in the 4-week dose-finding study (NCI 1978) and the Marhold et al. (1968) study, derivation of the MRL for hepatic effects is based on findings in the multi-dose study by Dodd et al. (2012). The selected study provides the best available data for characterizing the dose-response relationship for liver effects in laboratory animals orally exposed to 1,2-diphenylhydrazine for intermediate durations and it identified the lowest reliable LOAEL value.

Summary of the Principal Study:

Dodd DE, Pluta LJ, Sochaski MA, . 2012. Subchronic hepatotoxicity evaluation of hydrazobenzene in Fischer 344 rats. Int J Toxicol 31: 564–571.23134713

Groups of male Fischer 344 rats (minimum 10/group) were exposed to 0, 5, 20, 80, 200, or 300 ppm 1,2-diphenylhydrazine in the diet for 4 or 13 weeks. Mean administered doses, calculated from weekly food consumption and analytic diet concentration data, were reported to be 0, 0.32, 1.26, 4.80, 10.3, and 15.5 mg/kg/day. Endpoints evaluated included clinical observations, body weight, food consumption, serum chemistry, liver weights, gross pathology, and liver histopathology. Significant, but marginal decreases in body weights (up to ~6% decrease, compared with control values) beginning at 8 weeks occurred in animals exposed to 15.5 mg/kg/day. There were no clinical signs of toxicity or gross pathology throughout the study or at necropsy. Microscopic alterations in the liver, including slight/mild hypertrophy, minimal eosinophilic granular cytoplasm, multifocal bile duct duplications, and multifocal macrovesiculation, an indicator of lipid accumulation within hepatocytes, were observed only at 13 weeks at doses ≥10.3 mg/kg/day; the incidences of these lesions are presented in Table A-1. Relative liver weights also significantly increased (7.7 and 4.4%) at 4 and 13 weeks in 10.3 mg/kg/day rats, and showed concentration dependence, with increases of 8.5 and 10.7% at the same time points after treatment with 15.5 mg/kg/day. No consistent changes in serum alanine aminotransferase, total bilirubin, or lactate dehydrogenase were observed at any dose, but serum aspartate aminotransferase decreased by 26% at 13 weeks after treatment with 15.5 mg/kg/day. Decreases in serum alkaline phosphatase occurred beginning at a dose of 1.26 mg/kg/day at 13 weeks, but were also observed at earlier time points at higher doses; the toxicological significance of the decreases in alkaline phosphatase is not known. The investigators noted that the decreases were unexpected and did not correlate with other liver effects (Dodd et al. 2012).

Table A-1 Incidences of Liver Lesions in Rats Exposed to 1,2-Diphenylhydrazine in the Diet for 13 Weeks

| Dose (mg/kg/day)
| 0 | 0.32 | 1.26 | 4.80 | 10.3 | 15.5
Slight/mild hypertrophy (diffuse) | 0/12 | 0/10 | 0/10 | 0/10 | 10/10 | 10/10
Slight/mild macrovesiculation (multifocal) | 0/12 | 0/10 | 0/10 | 0/10 | 1/10 | 10/10
Minimal eosinophilic granular cytoplasm | 0/12 | 0/10 | 0/10 | 0/10 | 10/10 | 9/10
Minimal to slight/mild bile duct duplication (multifocal) | 0/12 | 0/10 | 0/10 | 0/10 | 8/10 | 10/10

Source: Dodd et al. 2012

Selection of the Point of Departure for the MRL: Data were not amenable to benchmark dose modeling due to the steep dose-response curve and the lack of information between the extremes of the control incidence (0%) and the maximal response (≥80%). Using a NOAEL/LOAEL approach, the NOAEL of 4.8 mg/kg/day for the absence of histopathological alterations in the liver was selected as the basis of the MRL.

Adjustment Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL of 4.8 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

- MRL = NOAEL ÷ UF
- 4.8 mg/kg/day ÷ (10 × 10) = 0.048 mg/kg/day ≈ 0.05 mg/kg/day

Other Additional Studies or Pertinent Information: In a chronic-duration study, dietary exposure to 1,2-diphenylhydrazine resulted in interstitial inflammation in the lungs, hyperkeratosis/acanthosis in the stomach, and fatty metamorphosis in the liver of rats exposed for 78 weeks (NCI 1978). Coagulative necrosis was also observed in the livers of female mice exposed to 52 mg/kg/day (NCI 1978). The results of the NCI (1978) study support the selection of the liver lesions as the most sensitive effect.

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Diphenylhydrazine
CAS Numbers: | 122-77-6
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The available chronic oral data (NCI 1978) were not considered adequate for derivation of a chronic oral MRL.

Rationale for Not Deriving an MRL: The only available chronic-duration oral study was not considered suitable for derivation of an MRL due to the long duration (28–30 weeks) between exposure termination and histological examination and methodological problems with the only available study.

The NCI (1978) bioassay of 1,2-diphenylhydrazine provides the only sufficient chronic oral toxicity data for this chemical. In this study, rats and mice were exposed to 1,2-diphenylhydrazine in the diet for 78 weeks followed by a 28–30-week observation period. The facilities supplying the rats, the diet, and the bedding used for low-dose rats and their controls differed from those used for the high-dose rats and their controls. Additionally, the low-dose control group and low- and high-dose exposed rats were housed in a different room than the high-dose control group. Similar differences in animal husbandry were noted for the mice. All animals, regardless of time or reason for death, whether due to lethality, sacrifice when moribund, or at study termination, were necropsied and were included in histopathological incidence evaluations. Significant increases in mortality were observed in female rats exposed to 9.2 mg/kg/day and in male and female mice exposed to 69 mg/kg/day; times and causes of death were not provided (NCI 1978). Non-neoplastic alterations included interstitial lung inflammation, acanthosis of the stomach, hyperkeratosis of the stomach, and fatty metamorphosis in the liver; the NOAEL and LOAEL values for these effects are presented in Table A-2. Although the study identifies 3.7 mg/kg/day as the lowest LOAEL for interstitial lung inflammation and acanthosis of the stomach in female rats, there is some uncertainty with this categorization, since the incidences of these lesions were not significantly increased at the higher dose level (9.2 mg/kg/day). Adding to the uncertainty is the inconsistency of these effects between the low-dose control group and the high-dose control group; for example, incidences of lung interstitial inflammation was 0/47 for the low-dose female controls and 6/50 in the high-dose female controls (in males, the incidences were 0/47 and 4/48 in low- and high-dose controls). In addition to these non-neoplastic lesions, increases in the incidence of neoplastic lesions were observed, including hepatocellular carcinomas in male rats exposed to ≥6.3 mg/kg/day and female mice exposed to 69 mg/kg/day, neoplastic nodules in the livers of female rats exposed to 9.2 mg/kg/day, combined squamous cell carcinomas/papillomas in the ear canal, Zymbal’s gland, and skin of the ear in male rats exposed to 24 mg/kg/day, adrenal gland pheochromacytomas in male rats exposed to 24 mg/kg/day, and mammary gland adenocarcinomas in female rats exposed to 9.2 mg/kg/day (NCI 1978).

Table A-2 Summary of Relevant NOAEL and LOAEL Values in Rats and Mice Following Chronic-Duration Oral Exposure to 1,2-Diphenylhydrazine^a^

| Males | | Females
| NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day)
Fischer 344 rats
Increased mortality | | | | 9.2
Decreased body weight gain | 6.3 | 24 | 3.7 | 9.2
Interstitial lung inflammation | | 6.3 | | 3.7^b^
Acanthosis of stomach | 6.3 | 24 | | 3.7^b^
Hyperkeratosis of stomach | 6.3 | 24 | 9.2
Fatty metamorphosis in liver | 6.3 | 24 | 3.7 | 9.2^c^
B6C3F1 mice
Increased mortality | | 69 | | 69
Decreased body weight | 14 | 69 | 6.9 | 69
Coagulative hepatic necrosis | | | 6.9 | 69

a Rats and mice were exposed for 78 weeks followed by a 28–30-week observation period.

b This effect was not observed in rats exposed to 9.2 mg/kg/day.

c Incidence higher than low-dose control group, but not high-dose control group.

Source: NCI 1978

The NCI (1978) study was not considered suitable for the derivation of a chronic-duration oral MRL due to the lack of dose-response for effects observed at the lowest dose tested, the long recovery period, and some methodological issues with the study design. As summarized in Table A-3, significant increases in the incidence of interstitial lung inflammation and acanthosis of the stomach were observed in female rats at the lowest dose tested (3.7 mg/kg/day), but were not observed at the highest dose (9.2 mg/kg/day). In male rats, an increase in interstitial lung inflammation was observed in male rats at 6.3 and 24 mg/kg/day. Stomach lesions were observed in males at 24 mg/kg/day, but not at 6.3 mg/kg/day. The lack of dose-response relationships increases the uncertainty in assessing whether the effects are due to 1,2-diphenylhydrazine exposure. Differences in the source of the animals, housing, and diet between the low-dose controls and exposed animals and the high-dose controls and exposed animals may have also contributed to the observed differences. In addition, the long recovery period complicates the identification of the NOAELs and LOAELs because it is not known if effects occurred at lower doses and the damage was repaired prior to examination.

Table A-3 Incidence of Lung and Stomach Lesions in Rats Following Chronic-Duration Oral Exposure to 1,2-Diphenylhydrazine^a^

Female rats | Low dose | | High dose
Female rats | Controls | 3.7 mg/kg/day | Controls | 9.2 mg/kg/day
Interstitial lung inflammation | 0/47 (0%) | 29/50^b^ (58%) | 6/50 (12%) | 7/50 (14%)
Acanthosis of stomach | 0/46 (0%) | 6/50^b^ (12%) | 2/48 (4%) | 5/44 (11%)
Male rats | Low dose | | High dose
Male rats | Controls | 6.3 mg/kg/day | Controls | 24 mg/kg/day
Interstitial lung inflammation | 0/47 (0%) | 12/49^b^ (24%) | 4/48 (8%) | 16/48^b^ (33%)
Acanthosis of stomach | 0/47 (0%) | 4/49 (8%) | 1/49 (2%) | 17/47^b^ (36%)

a Rats were exposed for 78 weeks followed by a 28–30-week observation period.

b Statistically significant differences (p<0.05); Fisher Exact Test conducted by ATSDR.

Source: NCI 1978

Agency Contact (Chemical Manager): Sam Keith, M.S., C.H.P.