# 8 REFERENCES

*Cited in text

Al-Badry MS, Knowles CO. 1980. Phthalate-organophosphate interactions: Toxicity, penetration, and metabolism studies with house flies. Arch Environ Contam Toxicol 9:147–161.6155828
Alaimo LH, Hartman TG, Rosen RT, . 1990. Nonpriority analysis of the wastewater streams of four dye manufacturing facilities. Res J WPCF 62:665–669.
*Albro PW, Moore B. 1974. Identification of the metabolites of simple phthalate diesters in rat urine. J Chromatogr 94:209–218.4844611
*Albro PW, Thomas R, Fishbein L. 1973. Metabolism of diethylhexyl phthalate by rats: Isolation and characterization of the urinary metabolites. J Chromotogr 76:321–330.
*APHA. 1992. American Public Health Association. Standard methods for the examination of water and wastewater. 18th Edition. Washington, DC: American Public Health Association.
Armstrong VC, Newhook RC. 1992. Assessing the health risks of priority substances under the Canadian environmental protection act. Regulatory Toxicol Pharmacol 15:111–121.
*ATSDR. 1988. Health assessment for Dixie Caverns Landfill, Salem, Virginia. Agency for Toxic Substances and Disease Registry, Atlanta, GA. PB90-144478.
ATSDR. 1989a. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Federal Register 54:37618–37634.
*ATSDR. 1989b. Health assessment for Butler Mine Tunnel, Pittson, Pennsylvania. Agency for Toxic Substances and Disease Registry, Atlanta, GA. PB90-143603.
*ATSDR. 1989c. Health assessment for Revere Chemical Company National Priorities List (NPL) site, Revere Bucks County, Pennsylvania. Agency for Toxic Substances and Disease Registry, Atlanta, GA. PB90-144759.
*ATSDR. 1992. Toxicological profile for di(2-ethylhexyl)phthalate. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486. -.3222488
Bennett GF. 1989. Impact of toxic chemicals on local wastewater treatment plant and the environment. Environ Geol Water Sci 3:201–212.
Bernstein ME. 1984. Agents affecting the male reproductive system: Effects of structure on activity. Drug Metab Rev 15:941–996.6396061
Bower RK, Haberman S, Minton PD. 1970. Teratogenic effects in the chick embryo caused by esters of phthalic acid. J Pharmacol Exp Ther 171:314–324.5459065
*Brodsky J, Andersson JT, Ballschmiter K. 1986. Chemical degradation of xenobiotics: II. Simulation of the biotic transformation of bis(Zethylhexy1) phthalate and dioctylphthalate by abiotic means. Chemosphere 15:139–147.
Brunetti G, Moscato G. 1984. Bronchial asthma due to occupational exposure to DOP. Med Lav 75:120–124.6749048
Carmignani GM, Bennett JP. 1976. Leaching of plastics used in closed aquaculture systems. Aquaculture 7 :89–91.
*Carter JH, Richmond RE, Carter HW, . 1992. Quantitative image cytometry of hepatocytes expressing gamma-glutamyl transpeptidase and glutathione S-transferase in diethylnitrosamine-initiated rats treated with phenobarbital and/or phthalate esters. J Histochem Cytochem 40: 1105–1115.1352315
*Clayton GD, Clayton FE, eds. 1981. Patty’s industrial hygiene and toxciology. Volume 2A: Toxicology. 3rd revised ed. New York, NY: John Wiley and Sons, 2343–2351.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. Journal WPCF 56(7):898–908.
Comu MC, Lhuguenot JC, Brady AM, . 1992. Identification of the proximate peroxisome proliferators derived from di(ethylhexy1) adipate and species differences in response. Biochem Pharmacol 43:2129–2134.1599500
*DeAngelo AB, Garrett CT, Manolukas LA, . 1986. Di-n-octyl phthalate (DOP), a relatively ineffective peroxisome inducing straight chain isomer of the environmental contaminant di(2-ethylhexyl)phthalate (DEHP), enhances the development of putative preneoplastic lesions in rat liver. Toxicology 41:279–288.2877511
*DeLeon IR, Byrne CJ, Peuler EA, . 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15(6):795–805.
Dillingham EO, Autian J. 1973. Teratogenicity, mutagenicity, and cellular toxicity of phthalate esters. Environ Health Perspect 81–89.
Dirven HA, Theuws JL, Jongeneelen FJ, . 1991. Non-mutagenicity of 4 metabolites of di(2-ethylhexyl)phthalate (DEHP) and 3 structurally related derivatives of di(2-ethylhexyl)adipate (DEHA) in the salmonella mutagenicity assay. Mutat Res 260:121–130.2027336
*Dogra RK, Chandra K, Chandra S, . 1989. Di-octyl phthalate induced altered host resistance: Viral and protozal models in mice. Industrial Health 27:83–87.2545652
*Dogra RK, Khanna S, Nagale SL, . 1985. Effect of dioctyl phthalate on immune system of rat. Indian J Exp Bio 23:315–319.4077130
*Dogra RK, Khanna S, Shukla L, . 1987. Modification of the immune response in rats by di-octyl phthalate. Industrial Health 25:97–101.3624008
*Eastman Kodak Company. 1978. Toxicity and health hazard summary. Rochester, NY: EPA/OTS Document No. 878214345.
*Eichelberger JW, Kerns EH, Okynyk P, . 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
*EPA. 1979. Water-related environmental fate of 129 priority pollutants. Volume II. Washington, DC: Monitoring and Data Support Division, U.S. Environmental Protection Agency. EPA Report No. 440/4-79-029b, 94: 1-28.
EPA. 1980. U.S. Environmental Protection Agency. Federal Register 45:33132–33133.
*EPA. 1981. Determination of phthalates in industrial and municipal waste waters. Technical report. Cincinnati, OH: U.S. Environmental Protection Agency. EPA-600/4-81-063.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: Monitoring and Data Support Division, Office of Water Regulations and Standards, U.S. Environmental Protection Agency. EPA Report No. 440/4-81-014.
EPA. 1985. U.S. Environmental Protection Agency. 40 CFR 122.1, 122 Appendix D.
*EPA. 1986a. Test methods for evaluating solid waste (SW-846). Volume IC: Laboratory manual physical/chemical methods. Method 8270. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986b. Test methods for evaluating solid waste (SW-846). Volume IC: Laboratory manual physical/chemical methods. Method 8250. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986c. Test methods for evaluating solid waste (SW-846). Volume IC: Laboratory manual physical/chemical methods. Method 8060. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986d. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*EPA. 1986e. Toxic and priority organics in municipal sludge land treatment systems. Cincinnati, OH: Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Wastewater Engineering Research Laboratory. EPA/600/2-86/010.
*EPA. 1987a. Health and environmental effects profile for phthalic acid esters (PAEs). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. PB89-120158.
*EPA. 1987b. Health effects assessment for selected phthalic acid esters. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. PB88-178934.
EPA. 1987c. U.S. Environmental Protection Agency. Part II. Federal Register 52:25942–25953.
EPA. 1987d. U.S. Environmental Protection Agency. Part II. Federal Register 52:13370, 13379–13381.
EPA. 1988a. U.S. Environmental Protection Agency. 40 CFR 401.16, 403, APPENDIX B
EPA. 1988b. U.S. Environmental Protection Agency. Part II. Federal Register 53:4500–4507.
EPA. 1988c. U.S. Environmental Protection Agency. Part V. Federal Register 53:38642–38654.
EPA. 1989a. U.S. Environmental Protection Agency final report. NHATS broad scan analysis: Population estimates from fiscal year 1982 specimens. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA 560/5-90-001.
*EPA. 1989b. U.S. Environmental Protection Agency. Part V. Federal Register 54:33418–33419, 33457.
*EPA. 1990a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*EPA. 1990b. Method 1625 revision B. Semivolatile organic compounds by isotope dilution GCYMS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Ch.l:516–536.
EPA. 1990c. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22537, 22593, 22712.
EPA. 1991a. U.S. Environmental Protection Agency. 40 CFR 261, Appendix VIII.
EPA. 1991b. U.S. Environmental Protection Agency. Part II. Federal Register 55:3864–3910.
*EPA. 1992a. Chemistry report on di-n-octylphthalate. Washington, DC: Industrial Chemistry Branch, Economics and Technology Division, Office of Toxic Substances, U.S. Environmental Protection Agency.
*EPA. 1992b. Heast Table 1: Subchronic and chronic toxicity (other than carcinogenicity). Health Effects Assessment Summary Tables. U.S. Environmental Protection Agency. NTIS Order No. PB92-921199.
*EPA. 1992c. Di-n-octylphthalate exposure report for delisting petition. U.S. Environmental Protection Agency, Washington, DC. Memorandum from Annett Nold, Exposure Assessment Branch, Exposure Evaluation Division, Office of Pollution Prevention and Toxics to Ken Mitchell, Toxics Release Inventory Management Staff, Economics and Technology Division, Office of Pollution Prevention and Toxics. September 21, 1992.
*EPA. 1992d. Transmittal of hazard assessment of di-n-octyl phthalate. Washington, DC: U.S. Environmental Protection Agency, Washington, DC. Memorandum from Lorraine Randecker, Chemical Review and Evaluation Branch, Health and Environmental Review Division, Office of Pollution Prevention and Toxics to Ken Mitchell, Toxics Release Inventory Management Staff, Economics and Technology Division, Office of Pollution Prevention and Toxics. July 15, 1992.
*EPA. 1993a. Di-n-octyl phthalate; toxic chemical release reporting; community right-to-know. U.S. Environmental Protection Agency. Federal Register 58(8):4133–4137.
*EPA. 1993b. Di-n-octyl phthalate; toxic chemical release reporting; community right-to-know. U.S. Environmental Protection Agency. Federal Register 58(191):51785–51786.
EPA. 1993c. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372 Subpart D.
*EPA. 1995a. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30.
*EPA. 1995b. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120.
*EPA. 1995c. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 122 Appendix D.
*EPA. 1995d. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 403 Appendix B.
*EPA. 1995e. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 268.
*EPA. 1995f. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261 Appendix VIII.
*EPA. 1995g. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264 Appendix IX.
*EPA. 1995h. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.
*EPA. 19951. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 175.105.
FDA. 1977. Food and Drug Administration, Health and Human Services. 21 CFR 175.105.
FDA. 1992. Food and Drug Administration, Health and Human Services. 21 CFR 177.2600.
*FDA. 1995a. U.S. Food and Drug Administration. Code of Federal Regulations 21 CI% 175.105.
*FDA. 1995b. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 177.2600.
Ferrario JB, DeLeon IR, Tracy RE. 1985. Evidence for toxic anthropogenic chemicals in human thrombogenic coronary plaques. Arch Environ Contam Toxicol 14:529–534.4051565
*Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames test. Toxicology 18219–232.
*Foster PM, Thomas LV, Cook MW, . 1980. Study of the testicular effects and changes in zinc excretion produced by some n-alkyl phthalates in the rat. Toxicol Appl Pharmacol 54:392–398.7394794
Fracasso A, Bazzato G, Kurtzman NA, . 1986. Plasticizers from peritoneal dialysis tubing and bags inhibit water transport in vitro. Clinical Res 34:729A.
*Fredricsson B, Moeller L, Pousette A, . 1993. Human sperm motility is affected by plasticizers and diesel particle extracts. Pharmacol Toxicol (Copenhagen) 72(2):128–133.
*Furtmann K. 1994. Phthalates in surface water-a method for routine trace level analysis. Fresenius’ Journal of Analytical Chemistry 348(4):291–296.
Gangolli SD. 1982. Testicular effects of phthalate esters. Environ Health Perspect 45:77–84.6754364
Garrett NE, Lewtas J. 1983. Cellular toxicity in Chinese hamster ovary cell cultures: I. Analysis of cytotoxicity endpoints for twenty-nine priority pollutants. Environ Res 32:455–465.6641673
Geertz W, Dyer K, Johnson D, . 1974. Polyvinyl chloride biomedical products: Toxicity testing and identification of additives. Trans Am Sot Artif Int Organs 42–46.
Gesler RM. 1973. Toxicology of di-2-ethylhexyl phthalate and other phthalic acid ester plasticizers. Environ Health Perspect 73–79.
Giam CS, Wong MK. 1987. Plasticizers in food. J Food Protection 50:769–782.
Goldstein DB, Feistner GJ, Faull KF, . 1987. Plasticizers as contaminants in commercial ethanol. Alcoholism: Clinical and Experimental Research 11:521–524.2829649
*Goodyear Tire and Rubber Company. 1981a. Mutagenicity evaluation of dopine (dioctyl phthalate), BASF, Tank 28. Salmonella typhimurium/microsome bioassay. Akron, OH: Goodyear Tire and Rubber Company Laboratory Report No. 80-l l-5.
*Goodyear Tire and Rubber Company. 1981b. DNA Damage by dioctyl phthalate BASF, Tank 28 in the E. coli Pol A,- Assay. Akron, OH: Goodyear Tire and Rubber Company Laboratory Report No. 81-42-2.
*Gray TJ, Butterworth KR. 1980. Testicular atrophy produced by phthalate esters. Arch Toxicol Suppl 4:452–455.6776936
Guess WL, Haberman S. 1968. Toxicity profiles of vinyl and polyolefinic plastics and their additives. J Biomed Mater Res 2:313–335.5708015
*Hardin BD, Schuler RL, Burg JR, . 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratogenesis Carcinogen Mutagen 7:29–48.
*HazDat. 1995. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Heindel JJ, Gulati DK, Mounce RC, . 1989. Reproductive toxicity of three phthalic acid esters in a continuous breeding protocol. Fundam Appl Toxicol 12:508–518.2731665
*Hinton RH, Mitchell FE, Mann A, . 1986. Effects of phthalic acid esters on the liver and thyroid. Environ Health Perspect 70:195–210.3830106
*Howard PH, Boethling RS, Jarvis WF, ., eds. 1991. Handbook of environmental degradation rates, New York, NY: Lewis Publishers.
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology-Information Program, Bethesda, MD.
Hüls AG. 1989. Phthalic acid, di-n-octylphthalate, n-decyl ester: Bacterial mutation assay. Huntingdon Research Centre. Huntingdon, England. DNN 64/901441.
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. March 13, 1995.
Johnson BT, Heitkamp MA, Jones JR. 1984. Environmental and chemical factors influencing the biodegradation of phthalic acid esters in freshwater sediments. Environ Pollut 8:101–118.
Jones AE, Kahn RH, Groves JT, . 1975. Phthalate ester toxicity in human cell cultures. Toxicol Appl Pharmacol 31:283–289.1129799
*Jones HB, Garside DA, Liu R, . 1993. The influence of phthalate esters on Leydig cell structure and function in vitro and in vivo. Exp Mol Path01 58(3):179–193.
Jones TD, Walsh PJ, Zeighami EA. 1985. Permissible concentrations of chemicals in air and water derived from RTECS entries: A “rash” chemical scoring system. Toxicol Ind Health 1:213–234.3843502
*Jungclaus GA, Lopez-Avila V, Hites RA. 1978. Organic compounds in an industrial wastewater: A case study of their environmental impact. Environ Sci Technol 12:88–96.
Kalman DA. 1986. Survey analysis of volatile organics released from plastics under thermal stress, Am Ind Hyg Assoc J 47:270–275.3717010
Kandala JC, DeAngelo AB, Reddy TV, . 1993. Transcriptional changes in hepatic tumors of rats induced by di(2-ethylhexyl) phthalate and di-n-octyl phthalate. Environmental Science (Tokyo) 2(3):147–159.
Kaya K, Nohara K. 1987. Effect of di-n-octyl phthalate on fatty acid composition of phosphatidylcholine in tetrahymena. Chem Biol Interactions 64:93–101.
Khanna S, Dogra RK, Bhatnagar MC, . 1989. Light and electronmicroscopic changes in testis of di-octyl phthalate treated rats. J Environ Biol 10:355–362.
Klaunig JE, Ruth RJ, DeAngelo AB, . 1988. Inhibition of mouse hepatocyte intercellular communication by phthalate monoesters. Cancer Lett 43:65–71.3203332
Kluwe WM. 1982. Overview of phthalate ester pharmacokinetics in mammalian species. Environ Health Perspect 45:3–9.6754362
Kluwe WM, McConnell EE, Huff JE, . 1982. Carcinogenicity testing of phthalate esters and related compounds by the National Toxicology Program and the National Cancer Institute. Environ Health Perspect 45:129–133.7140685
Kondyli E, Demertzis PG, Kontominas MG. 1992. Migration of dioctylphthalate and dioctyladipate plasticizers from food-grade PVC films into ground-meat products. Food Chem 45:163–168.
Kool HJ, van Kreijl CF, Zoeteman CJ. 1983. Toxicology assessment of organic compounds in drinking water. CRC Criteria1 Reviews in Environmental Control 12:307–357.
Korhonen A, Hemminki K, Vainio H. 1983a. Embryotoxic effects of phthalic acid derivatives, phosphates and aromatic oils used in the manufacturing of rubber on three day chicken embryos. Drug Chem Toxicol 6:191–207.6872883
Korhonen A, Hemminki K, Vainio H. 1983b. Toxicity of rubber chemicals towards three-day chicken embryos. Stand J Work Environ Health 9:115–119.
*Lake BG, Gray TJ, Gangolli SD. 1986. Hepatic effects of phthalate esters and related compounds - in vivo and in vitro correlations. Environ Health Perspect 67:283–290.3757955
*Lake BG, Phillips JC, Linnell JC, . 1977. The in vitro hydrolysis of some phthalate diesters by hepatic and intestinal preparations from various species. Toxicol Appl Pharmacol 39:239–248.403636
*Lake BG, Rijcken WR, Gray TJ, . 1984. Comparative studies of the hepatic effects of di- and mono-n-octyl phthalates, di-(Zethylhexyl) phthalate and clofibrate in the rat. Acta Pharmacol Toxicol 54:167–176.
*Lanina SY, Strakhova NM, Lappo VG. 1992. Toxicological estimate of polyvinyl chloride containers for preparation and storage of blood, its components, preservatives and infusion solutions. Med Prog Tech 18:19–22.
*Ligocki MP, Leuenber C, Pankow JF. 1985. Trace organic compounds in rain: II. Gas scavenging of neutral organic compounds. Atmospheric Environ 19(10):1609–1617.
*Lopez-Avila V, Milanes J, Dodhiwala NS, . 1989. Cleanup of environmental sample extracts using florisil solid-phase extraction cartridges. J Chromatogr Sci 27(5):209–220.2745661
Mabey WR, Smith JH, Pod011 RT, . 1982. Aquatic fate process data for organic priority pollutants. Report to U.S. Environmental Protection Agency, Office of Water Regulations and Standards, Washington, DC, by SRI International, Menlo Park, CA. EPA 440/4-81-014.
Mallette FS, von Haam E. 1952. Studies on the toxicity and skin effects of compounds used in the rubber and plastics industries. Ind Hyg Occup Med 231–236.
*Mann AH, Price SC, Mitchell FE, . 1985. Comparison of the short-term effects of di(2-ethylhexyl) phthalate, di(n-hexyl)phthalate, and di(n-octyl)phthalate in rats. Toxicol Appl Pharmacol 77:116–132.3966235
*Mannsville Chemical Products Corporation. 1989. Dioctyl phthalate. Chemical products synopsis, Mannsville Chemical Products Corporation, Asbury Park, NJ.
*Mathur SP. 1974a. Phthalate esters in the environment: Pollutants or natural products? J Environ Qua1 3(3):189–197.
*Mathur SP. 1974b. Respirometric evidence of the utilization of di-octyl and di-2-ethylhexyl phthalate plasticizers. J Environ Quality 3:207–209.
*Morrissey RE, Lamb JC, Morris RW, . 1989. Results and evaluations of 48 continuous breeding reproduction studies conducted in mice. Fundam Appl Toxicol 13:747–777.2620795
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
Nematollahi J, Guess WL, Autian J. 1967. Plasticizers in medical application: I. Analysis and toxicity evaluation of dialkyl benzenedicarboxylates. J Pharmacol Sci 56:1446–1453.
*NIOSH. 1983. Screening of priority chemicals for potential reproductive hazard. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control. NTIS Order No. PB85-220143.
*NIOSH. 1993. National Occupational Exposure Survey. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control. March 10, 1993.
*NIOSH RTECS. 1987. Registry of toxic effects of chemical substances. 1985-1986 Edition. Volume 4. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 3461.
NTP. 1982a. NTP technical bulletin. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, 7.
NTP. 1982b. NTP technical bulletin. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, 8.
*NTP. 1985. Di-n-octylphthalate: Reproduction and fertility assessment in CD-l mice when administered in feed. Research Triangle Park, NC: National Institute of Environmental Health Sciences, National Toxicology Program. NTP-85-140. NTIS Order No. PB85-218147.
*Oishi S. 1990. Effects of phthalic acid esters on testicular mitochondrial functions in the rat. Arch Toxicol 64:143–147.2350233
*Oishi S, Hiraga K. 1980. Testicular atrophy induced by phthalic acid esters: Effect on testosterone and zinc concentrations. Toxicol Appl Pharmacol 53:35–41.7385236
*Oishi S, Hiraga K. 1982. Effects of monoesters of O-phthalic acid on serum lipid composition of rats. Toxicol Lett 14:79–84.7157420
Perwak, Goyer M, Schimke G, . 1980. An exposure and risk assessment for phthalate esters. Final draft report. Washington, DC: U.S. Environmental Protection Agency, Office of Water and Waste Management.
*Peterson JC, Freeman DH. 1984. Variations of phthalate ester concentrations in sediments from the Chester River, Maryland. Inter J Environ Anal Chem 18:237–252.
*Petrasek AC, Kugelman IJ, Austern BM, . 1983. Fate of toxic organic compounds in wastewater treatment plants. J WPCF 55:1286–1296.
Phillips LJ. 1992. Regional relationships between toxic releases, and environmental and human exposure to toxic substances. Bull Environ Contam Toxicol 48:795–802.1568055
*Peon R, Lecavalier P, Mueller R, . 1995. Subchronic oral toxicity of di-n-octylphthalate and di(2-ethylhexyl)phthalate in the rat. [ATSDR peer-reviewed draft].
*Ritsema R, Cofino WP, Frintop PCM, . 1989. Trace-level analysis of phthalate esters in surface water and suspended particulate matter by means of capillary gas chromatography with electron-capture and mass-selective detection. Chemosphere 18:2161–2175.
Russell D, McDuffie B. 1986. Chemodynamic properties of phthalate esters: Partitioning and soil migration. Chemosphere 15:1003–1021.
Sabatini S, Fracasso A, Bazzato G, . 1989. Effect of phthalate acid esters on transport in toad bladder membrane. J Pharmacol Exp Ther 250:910–914.2550621
Sanborn JR, Metcalf RL, Yu CC, . 1975. Plasticizers in the environment: The fate of di-n-octyl phthalate (DOP) in two model ecosystems and uptake and metabolism of DOP by aquatic organisms. Arch Environ Contam Toxicol 3:244–255.1155967
*Sato T, Nagase H, Sato K, . 1994. Enhancement of the mutagenicity of amino acid pyrolysates by phthalate esters. Environ Mol Mut 24:325–331.
*Sax NI, Lewis RJ Sr. 1989. Dangerous properties of industrial materials. Volume II, 7th ed. New York, NY: Van Nostrand Reinhold, 1465–1466.
Schwartz BS, Ford DP, Bolla KI, . 1990. Solvent-associated decrements in olfactory function in paint manufacturing workers. Am J Ind Med 18:697–706.2264568
*Seed JL. 1982. Mutagenic activity of phthalate esters in bacterial liquid suspension assays. Environ Health Perspect 45:111–114.6754360
Shafer KH, Cooke M, DeRoos F, . 1981. WCOT capillary column GC/FT-IR and GC/MS for identifying toxic organic pollutants. Appl Spectroscopy 35:469–472.
*Shelton DR, Boyd SA, Tiedje JM. 1984. Anaerobic biodegradation of phthalic acid esters in sludge. Environ Sci Technol 18:93–97.22292682
*Shibamoto T, Wei CI. 1986. Mutagenicity of materials extracted from synthetic rubber. Agric Biol Chem 50:513–514.
*Singh AR, Lawrence WH, Autian J. 1972. Teratogenicity of phthalate esters in rats. J Pharm Sci 61(1):51–55.5058645
*Sittig M. 1991. Handbook of toxic and hazardous chemicals and carcinogens. Volume 1, 3rd ed. Park Road, NJ: Noyes Publications, 674–675.
*Stutz DR, Ulin S. 1992. Hazardous materials injuries: A handbook for pre-hospital care. Third edition. Beltsville, MD: Bradford Communications Corporation, 258–259.
Sugawara N. 1974. Toxic effect of a normal series of phthalate esters on the hatching of shrimp eggs. Toxicol Appl Pharmacol 30:87–89.
*Tabak HH, Quave SP, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Quality 1503–1517.
Takagi A, Sai K, Umemura T, . 1990. Significant increase of 8-hydroxyguanosine in liver DNA of rats following short-term exposure to the peroxisome proliferators di(2-ethylhexyl)phthalate and di(2-ethylhexyl)adipate. Jpn J Cancer Res 81:213–215.2112523
Takahashi T. 1977. Biochemical studies on phthalic esters: II. Effects of phthalic esters on mitochondrial respiration of rat liver. Biochem Pharmacol 26: 19–24.831723
Teranishi H, Kasuya M. 1980. The effects of phthalate esters on fibroblasts in primary culture. Toxicol Lett 6:11–15.7423538
*TRI92. 1994. Toxic Chemical Release Inventory. U.S. Environmental Protection Agency, Office of Toxic Substances, Washington, DC.
Urushigawa Y, Yonezawa Y. 1979. Chemico-biological interactions in biological purification systems: VI. Relation between biodegradation rate constants of di-n-alkyl phthalate esters and their retention times in reverse phase partition chromatography. Chemosphere 5:317–320.
USITC. 1986. Synthetic organic chemicals: United States production and sales. Washington, DC: United States International Trade Commission.
USITC. 1989. Synthetic organic chemicals: United States production and sales. Washington, DC: United States International Trade Commission.
*USITC. 1994. Synthetic organic chemicals: United States production and sales. Washington, DC: United States International Trade Commission.
*Valkenburg CA, Munslow WD, Butler LC. 1989. Evaluation of modifications to extraction procedures used in analysis of environmental samples from Superfund sites. J Assoc Off Anal Chem 72(4):602–608.
*Vista Chemical Company. 1992. Petition to delist di-n-octylphthalate under Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986. Submitted to U.S. Environmental Protection Agency. Austin, TX.
Walker JD. 1990. Review of chemical fate testing conducted under section 4 of the toxic substances control act: Chemicals, tests, and methods. J Bacterial 13:78–90.
*Wang YY, Marsden PJ, Flessel CP, . 1990. Evaluation and validation of protocols for measurement of the mutagenicity of environmental samples. In: Friedman D, ed. Waste testing and quality assurance: Second volume. STP 1062.
*Wild SR, Jones KC. 1992. Organic chemicals entering agricultural soils in sewage sludges: Screening for their potential to transfer to crop plants and livestock. Sci Total Environ 119:85–119.1631535
Williams DF. 1981. The toxicology of additives in medical plastics. In: Williams DF, ed. Systemic aspects of biocompatibility. Volume II. Boca Raton, FL: CRC Press, Inc., 145–157.
*Wolfe NL, Burns LA, Steen WC. 1980. Use of linear free energy relationships and an evaluate model to assess the fate and transport of phthalate esters in the aquatic environment. Chemosphere 9:393–402.
Yu X, Wang X, Bartha R, . 1990. Supercritical fluid extraction of coal tar contaminated soil. Environ Sci Technol 24:1732–1738.
*Zeiger E, Haworth S, Mortelmans K, . 1985. Mutagenecity testing of di(Zethylhexyl)phthalate and related chemicals in salmonella. Environ Mutagen 7:213–232.3971959
*Zeiger E, Haworth S, Speck W, . 1982. Phthalate ester testing in the National Toxicology Program’s environmental mutagenesis test development program. Environ Health Perspect 45:99–101.6754365