# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding di-n-octylphthalate in air, water, and other media are summarized in Table 7-1.

ATSDR has derived an MRL of 3 mg/kg/day for acute-duration oral exposure in humans; this MRL is based on a LOAEL of 1,000 mg/kg/day in rats (Lake et al. 1986).

ATSDR has derived an MRL of 0.4 mg/kg/day for intermediate-duration oral exposure in humans; this MRL is based on a NOAEL of 40.8 mg/kg/day in rats (Poon et al. 1995).

An oral reference dose (RfD) is currently pending by EPA (IRIS 1995).

Neither EPA or IARC has classified di-n-octylphthalate as to its carcinogenicity.

TABLE 7-1 Regulations and Guidelines Applicable to Di-n-octylphthalate

Agency | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. Water:
EPA OWRS | General permits under NPDES | Yes | EPA 1995c (40 CFR 122, Appendix D)
EPA OWRS | General Pretreatment Regulations for Existing and New Sources of Pollution | Yes | EPA 1995d (40 CFR 403, Appendix B)
b. Food:
FDA | Component of adhesives | Yes | FDA 1995a (21 CFR 175.105)
FDA | Use in rubber articles intended for repeated use | Yes | FDA 1995b (21 CFR 177.2600)
c. Other:
EPA OERR | Reportable quantity | 5000 pounds | EPA 1995i (40 CFR 302.4)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1995f (40 CFR 261, Appendix VIII)
EPA OSW | Groundwater Monitoring List (Appendix IX) | Yes | EPA 1995g (40 CFR 264, Appendix IX)
EPA OSW | Land Disposal Restrictions | Yes | EPA 1995e (40 CFR 268)
EPA OTS | Toxic Chemical Release Reporting Rule | No^a^ | EPA 1995h (40 CFR 372)
EPA OTS | Health and Safety Data Reporting Rule | No | EPA 1995b (40 CFR 716.120)
EPA OTS | Preliminary Assessment Information Reporting Rule | Yes | EPA 1995a (40 CFR 712.30)

a Delisted, effective 10/05/93. “EPA concluded that there is not sufficient evidence to establish that DNOP causes adverse acute human health effects, chronic human health effects, or environmental toxicity.” [FR 58(19):51785].

EPA = Environmental Protection Agency; FDA = Food and Drug Administration; NPDES = National Pollutant Discharge Elimination System; OERR = Office of Emergency and Remedial Response; OSW = Office of Solid Waste; OTS = Office of Toxic Substances; OWRS = Office of Water Regulations and Standards