# 4 PRODUCTION, IMPORT, USE, AND DISPOSAL

## 4.1 PRODUCTION

Di-n-octylphthalate is produced commercially as a component of mixed phthalate esters, including straight- chain C6, C8, and Cl0 phthalates (EPA 1993a). Di-n-octylphthalate is produced at atmospheric pressure or in a vacuum by heating an excess of n-octanol with phthalic anhydride in the presence of an esterification catalyst such as sulfuric acid or p-toluenesulfonic acid. The process may be either continuous or discontinuous (EPA 1993a; HSDB 1995). Di-n-octylphthalate can also be produced by the reaction of n-octylbromide with phthalic anhydride.

The most recent report available on di-n-octylphthalate lists three commercial producers: Vista Chemical Company, Houston, Texas; Aristech Chemical Corporation, Neville Island, Pennsylvania; and Teknor Apex Company, Hebronville, Massachusetts and Brownsville, Texas (EPA 1993a). Additional reported producers include: Eastman Kodak Company, Rochester, New York (USITC 1994); Tenneco Chemical, Inc., Chestertown, Maryland (EPA 1987a); Alfa Products, Morton Thiokol, Inc., Danvers, Massachusetts; Primachem, Inc., Englewood Cliffs, New Jersey; and GCA Chemical Corp., Stamford, Connecticut (HSDB 1995). Table 4-1 lists the U.S. facilities that manufacture or process di-n-octylphthalate.

The current annual production of di-n-octylphthalate is difficult to estimate because of confusion in nomenclature regarding the octylphthalate isomers and reported data describing only the entire group of dioctyl orthophthalates. A total of 122,384 metric tons of total dioctylphthalates were produced in 1992 (USITC 1994). The amount of di-n-octylphthalate included in this group was not reported because of the possible revelation of confidential business information.

Table 4-1 lists data from the Toxics Release Inventory (TRI) regarding U.S. companies that reported the manufacture and use of di-n-octylphthalate in 1992 (TR192 1994). The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list.

Table 4-1 Facilities That Manufacture or Process Di-n-octylphthalate

Facility | Location^a^ | Range of maximum amounts on site in pounds | Activities and uses
NA | AL | 10,000-99,999 | As a formulation component
HALSTEAD IND. INC. | AR | 10,000-99,999 | As a formulation component
GILLETTE CO. | CA | 1,000-9,999 | As a formulation component
NA | GA | 10,000-99,999 | Import; For sale/distribution; As a formulation component
NA | IL | 1,000-9,999 | As a formulation component
NA | IL | 1,000-9,999 | As a formulation component
NEW EXTRUSTIONS & FABRICATING | IL | 10,000-99,999 | As a formulation component; As a chemical processing aid; Ancillary uses
EASTERN INDUSTRIES | IL | 10,000-99,999 | As a product component
DOW CHEMICAL CO. | IL | 10,000-99,999 | As a formulation component
BRC RUBBER GROUP INC. | IN | 10,000-99,999 | As a formulation component
ATOCHEM N.A. INC. | KY | 10,000-99,999 | As a formulation component; As a chemical processing aid
VISTA CHEMICAL CO. | MA | 10,000-99,999 | As a formulation component
LEVITON MFG. | MA | 100,000-999,999 | As a product component
BRADFORD IND. INC. | MA | 1,000-9,999 | As a formulation component
NA | MA | 1,000-9,999 | As a formulation component
O’SULLIVAN CORP. | MA | 10,000-99,999 | As a formulation component
AMERICAN CYANAMID CO. | MI | 100-999 | Ancillary uses
GENERAL CABLE IND. INC. | MI | 10,000-99,999 | As a formulation component; As a product component
NA | MO | 1,000-9,999 | In repackaging only
GOODYEAR TIRE & RUBBER CO. | MO | 10,000-99,999 | As a reactant; As a formulation component
VISTA CHEMICAL CO. | MS | 100,000-999,999 | Produce; For on-site use/processing; For sale/distribution; As a formulation component
HALSTEAD IND. INC. | NC | 10,000-99,999 | As a formulation component
NA | NC | 1,000-9,999 | As a formulation component
UNIROYAL CHEMICAL CO. INC. | NC | 10,000-99,999 | As a formulation component
KONICA CORP. | NC | 1,000-9,999 | Ancillary uses
HBD INDUSTRIES INC. | NC | 10,000-99,999 | Import; For on-site use/processing; As a formulation component; As a chemical processing aid
PLASTICS SPECIALTIES & TECHNOL | NJ | 100,000-999,999 | As a formulation component
OCCIDENTAL PETROLEUM CORP. | NJ | 10,000-99,999 | As a formulation component
PLASTIC SPECIALTIES & TECHNOLO | NJ | 10,000-99,999 | As a formulation component
NA | NJ | 10,000-99,999 | As a formulation component
NA | NJ | 1,000-9,999 | As a formulation component
PLASTICS SPECIALTIES & TECHNOL | NV | 10,000-99,999 | As a formulation component
HM HOLDINGS INC. | NY | 1,000-9,999 | As a formulation component
NA | NY | 10,000-99,999 | As a product component
GOODYEAR TIRE & RUBBER CO. | OH | 1,000-9,999 | As a formulation component; As a product component; Ancillary uses
COOKSON AMERICA | OH | 10,000-99,999 | As a formulation component
BORDEN INC. | OH | 10,000-99,999 | As a product component
NA | OH | 100-999 | Import; For on-site use/processing; As a formulation component
A. SCHULMAN INC. | OH | 10,000-99,999 | As a formulation component
NA | OH | 1,000-9,999 | As a product component
ACC MIDDLE CORP. | PA | 100,000-999,999 | Produce; For sale/distribution
NA | PA | 10,000-99,999 | As a formulation component
NA | TN | 100-999 | As a formulation component
NA | TN | 10,000-99,999 | As a product component
GMC | TN | 100,000-999,999 | As a product component
NA | TN | 10,000-99,999 | As a formulation component
TEXAS IND. INC. | TX | 1,000-9,999 | Ancillary uses
TANDY CORP. | TX | 1,000-9,999 | As a formulation component
AMERON INC. | TX | 10,000-99,999 | As a reactant; As a formulation component
NA | UT | 10,000-99,999 | As a formulation component
NA | VA | 1,000-9,999 | As a formulation component
NA | VA | 100,000-999,999 | As a formulation component
UNIROYAL TECH. CORP. | WI | 10,000-99,999 | As a formulation component
NA | WI | 10,000-99,999 | As a formulation component
NA | WV | 10,000-99,999 | As a formulation component

Source: TRI92 1994

a Post office state abbreviations used

NA = not available

## 4.2 IMPORT/EXPORT

In 1988, 6 million pounds of di-octylphthalates (i.e., di-n-octylphthalate and di[2-ethylhexyl]phthalate) were imported and 37 million pounds were exported. No data were located on specific quantities for di-n-octylphthalate (Mannsville Chemical Products Corporation 1989).

## 4.3 USE

Di-n-octylphthalate is principally used as a plasticizer in the production of plastics (Sittig 1991) and PVC resins. When used as a plasticizer, di-n-octylphthalate can represent 5-60% of the total weight of the plastics and resins. It increases flexibility and enhances or alters the properties of the material. It is also used for cellulose ester and polystyrene resins, as a dye carrier in plastic production (primarily PVC), and as a chemical intermediate in the manufacture of adhesives, plastisols, and nitrocellulose lacquer coatings (EPA 1993a; HSDB 1995; Mannsville Chemical Products Corporation 1989). It is a registered active ingredient in pesticides (EPA 1987b) and is found in cosmetics and colorants (EPA 1992a). Di-n-octylphthalate also serves as a carrier for catalysts or initiators and as a substitute for electrical capacitor fluid (EPA 1992a).

Flexible PVC resins and other dioctylphthalate-containing plastics and resins are used in a variety of industrial and domestic products: plastisols for carpetback coating (EPA 1987b), film, wire, cables, and adhesives (HSDB 1995). Additional end-use products are automobile and furniture upholstery, wall coverings, window shades, garden hoses, shower curtains, tablecloths, rainwear, shoes, dolls, and toys (Mannsville Chemical Products Corporation 1989).

## 4.4 DISPOSAL

Di-n-octylphthalate, including waste containing di-n-octylphthalate, is classified as a hazardous waste product by EPA. Generators of waste containing this contaminant must conform to EPA regulations for treatment, storage, and disposal (see Chapter 7). Rotary kiln or fluidized bed incineration methods are acceptable disposal methods for these wastes. Liquid injection incineration may also be used (HSDB 1995).

According to the TRI, 240,609 pounds of di-n-octylphthalate were transferred to landfills and/or treatment/disposal facilities in 1992 (see Section 5.2) (TR192 1994). Of this quantity, about 1,475 pounds were discharged to publicly owned treatment works. A total of 15,302 pounds was released to air, land, and water by manufacturing and processing facilities. No di-n-octylphthalate was released for underground injection.