# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of di-n-octylphthalate is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the chemical and physical properties of di-n-octylphthalate is located in Table 3-2.

There is conflicting information for many of these properties in the literature. A possible explanation for the inconsistencies, as discussed in Chapter 2, may come from the use of the nonspecific term “di-octylphthalate.” This conflict has contributed to significant confusion and misinformation in the literature with respect to di-n-octylphthalate and the much more common isomer, di(2-ethylhexyl)phthalate. Although frequently being interpreted as referring to di-n-octylphthalate, it is apparent that in almost all cases “di-octylphthalate” and “DOP” have in fact been used as synonyms for di(2-ethylhexyl)phthalate. Therefore, many of the properties found for di-n-octylphthalate or di-octylphthalate may possibly be for di(2-ethylhexyl)phthalate.

TABLE 3-1 Chemical Identity of Di-n-octylphthalate

Characteristic | Information | Reference
Chemical name | Di-n-octylphthalate | HSDB 1995
Synonym(s) | 1,2-benzenedicarboxylic acid, di-n-octyl ester; 1,2-benzene-dicarboxylic acid, dioctyl ester; o-benzenedicarboxylic acid, dioctyl ester; DNOP; DOP; dioctyl 1,2-benzene-dicarboxylate; dioctyl o-benzenedicarboxylate; octyl phthalate; dioctyl phthalate; n-octyl phthalate; phthalic acid, dioctyl ester | HSDB 1995; EPA 1987a
Registered trade name(s) | Celluflux DOP; Dinopol NOP; Polycizer 162; PX-138; Vinicizer 85 | HSDB 1995
Chemical formula | C_24_H_38_O_4_ | HSDB 1995
Chemical structure | [image] | EPA 1987a
Identification numbers:
CAS registry | 117-84-0 | HSDB 1995
NIOSH RTECS | TI 1925000 | HSDB 1995
EPA hazardous waste | U 107 | HSDB 1995
OHM/TADS | 8300217 | HSDB 1995
DOT/UN/NA/IMCO shipping | No data
HSDB | 1345 | IRIS 1995
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Di-n-octylphthalate

Property | Information | Reference
Molecular weight | 390.54 | Clayton and Clayton 1981
Molecular weight | 390.56 | HSDB 1995
Molecular weight | 390.57 | EPA 1987b
Molecular weight | 390.62 | EPA 1987a; Sax and Lewis 1989; NIOSH RTECS 1987
Color | Colorless | EPA 1987a
Physical state | Liquid | EPA 1987a
Melting point | -25°C | EPA 1987a
Boiling point
at 760 mm Hg | 390–420°C | EPA 1993a
at 5 mm Hg | 230°C | Sittig 1991
at 4 mm Hg | 220–240°C | EPA 1987a
at 4 mm Hg | 220°C | HSDB 1995
Density:
at 25°C | 0.978 g/mL | HSDB 1995
Odor | Odorless | EPA 1993
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25°C | 0.2 mg/L | EPA 1992a
Water at 25°C | 3.0 mg/L | Wolfe et al. 1980; HSDB 1995
Organic solvent(s) | Soluble | EPA 1987a
Partition coefficients:
Log K_ow_ | 5.22 | EPA 1987a; HSDB 1995
Log K_oc_ | 4.28 | Wolfe et al. 1980
Vapor pressure at 25°C | 1.44×10^-4^ mm Hg | EPA 1987a
Henry’s law constant | 5.5×10^-6^ H atm-m^3^/mole | EPA 1992a
Henry’s law constant | 6.68×10^-5^ H atm-m^3^/mole | EPA 1992a
Autoignition temperature | No data
Flashpoint | 219°C | Sittig 1991
Flammability limits | No data
Conversion factors | No data
Explosive limits | No data