# APPENDIX A MINIMAL RISK LEVEL WORKSHEETS

## Di-n-octylphthalate Acute Oral

Chemical Name: | Di-n-octylphthalate
CAS Number: | 117-84-0
Date: | December 1995
Profile Status: | Post-Public Comment - Draft 3
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 5
Species : | Rat

[underlined: Minimal Risk Level:] [underlined: 3] [x] mg/kg/day [ ] ppm

[underlined: Reference:] Lake et al. 1986

[underlined: Experimental design:] Di-n-octylphthalate was administered (1,000 mg/kg/day) once/day for 14 days to a group of 4-6 male Sprague-Dawley rats. A group of male rats, administered the corn oil vehicle, served as controls. Following the last dose, animals were starved overnight and killed by cervical dislocation. Livers were excised to be weighed, then used for biochemical assays; histopathological examination was not performed.

[underlined: Effects noted in study and corresponding doses:] Liver effects were observed in treated rats. The hepatic effects consisted of a statistically significant (p < 0.01) increase (17 %) in relative liver weight and a reduction (approximately 30%) in 7-ethoxycoumarin O-deethylase activity relative to the vehicle control. Enzymatic indicators of peroxisome proliferation (KCN-insensitive palmitoyl-CoA oxidation or enoyl-CoA hydratase heat labile activity) were not significantly altered compared to controls. No significant changes in P-450 content or in the following activities were noted: ethylmorphine-N-demethylase, lauric acid 1 1-hydroxylation, and lauric acid 12-hydroxylation.

[underlined: Dose and end point used for MRL derivation:]

[ ] NOAEL [x] LOAEL (DOSE: 1000 mg/kg/day)

[underlined: Uncertaintv Factors used in MRL derivation:]

- [x] 3 for use of a minimal LOAEL
- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] No. If so, explain:

[underlined: If an inhalation study in animals. list the conversion factors used in determining human equivalent dose:]

[underlined: Other additional studies or pertinent information which lend support to this MRL:] The choice of liver toxicity as the basis for the acute oral MRL is supported by similar effects seen in other acute- and intermediate-duration studies in rats (DeAngelo et al. 1986; Lake et al. 1984; Mann et al. 1985).

## Di-n-octylphthalate Intermediate Oral

Chemical Name: | Di-n-octylphthalate
CAS Number: | 117-84-0
Date: | December 1995
Profile Status: | Post-Public Comment - Draft 3
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 2 1
Species: | Rat

[underlined: Minimal Risk Level:] [underlined: 0.4] [x] mg/kg/day [ ] ppm

[underlined: Reference:] Poon et al. 1995

[underlined: Experimental design:] Groups of 10 male and 10 female Sprague-Dawley rats were maintained on diets containing 0, 5, 50, 500, or 5,000 ppm di-n-octylphthalate (DNOP) in the diet for 13 weeks. The study authors determined that these dietary concentrations corresponded to doses of 0, 0.4, 3.5, 36.8, 350.1 mg/kg/day (males) and 0, 0.4, 4.1, 40.8, 402.9 mg/kg/day (females). Control animals received feed containing 4% corn oil. The rats were examined daily for clinical signs of toxicity, while food consumption and body weight data were collected weekly. At the end of the study, the animals were anesthetized with an i.p. injection of pentobarbital. Blood was collected from the aortic artery for hematological and biochemical determinations; enzymatic activity assays and comprehensive histopathological examinations were performed (although only data on the liver, thyroid, testis, and epididymis were presented).

[underlined: Effects noted in study and corresponding doses:] No clinical signs of toxicity or reduction in food consumption or body weight gain were noted. No treatment-related changes in organ weights were noted. At 5,000 ppm, increased (p < 0.05) calcium was noted in males. Liver effects observed in rats administered di-n-octylphthalate in the diet at a concentration of 5,000 ppm; the study authors calculated the doses at this concentration to be 350.1 mg/kg/day (males) and 402.9 mg/kg/day (females) (Peon et al. 1995). The hepatic effects consisted of a significant (p < 0.05) increases in ethoxyresorufin-0-deethylase activity (12-fold, males; 3-fold, females); no significant changes were noted in liver aminopyrine-N-demethylase or aniline hydrolase activities. Also, at 5,000 ppm, histopathological changes in hepatic architecture were noted, including moderate accentuation of zonation and mild-to-moderate increases in perivenous cytoplasmic vacuolation. Mild histological changes in the thyroid were also noted at 5,000 ppm that consisted of reduction in the follicle size and decreased colloid density. No effects were observed at 500 ppm (36.8 mg/kg/day for males and 40.8 mg/kg/day for females). The MRL was derived by dividing the NOAEL value of 40.8 mg/kg/day for hepatic effects by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

[underlined: Dose and end point used for MRL derivation:]

[x] NOAEL (DOSE: 40.8 mg/kg/day) [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation:]

- [ ] 10 for use of a LOAEL
- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] No. If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

[underlined: Other additional studies or pertinent information which lend support to this MRL:] The choice of liver toxicity as the basis of the MRL is supported by necrosis and mild hepatic fatty changes seen in other acute- and intermediate-duration studies in rats (DeAngelo et al. 1986; Lake et al. 1984, 1986; Mann et al. 1985). Thyroid toxicity (decreased thyroxine levels and ultrastructural changes) was observed after rats were fed 2,000 mg/kg/day of di-n-octylphthalate in the diet for 3, 10, or 21 days (Hinton et al. 1986).