# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

As summarized in Table 8-1, ATSDR has derived individual acute-duration oral MRLs for 6 DNT isomers (2,3-DNT, 2,4 DNT, 2,5-DNT, 2,6-DNT, 3,4-DNT and 3,5-DNT), intermediate-duration oral MRLs for 2,4-DNT and 2,6-DNT, and a chronic-duration oral MRL for 2,4-DNT.

The International Agency for Research on Cancer (IARC) classifies 2,4- and 2,6-DNT as Group 2B carcinogens (possibly carcinogenic to humans) and 3,5-DNT as a Group 3 carcinogen (not classifiable as to its carcinogenicity to humans) (IARC 2015). The U.S. EPA classifies the 2,4-/2,6-DNT mixture as B2 (probable human carcinogen) (IRIS 2003). The American Conference of Governmental Industrial Hygienists (ACGIH) has classified the 2,4-/2,6-DNT mixture as an A3 carcinogen (confirmed animal carcinogen with unknown relevance to humans) (ACGIH 2014).

OSHA requires employers of workers who are occupationally exposed to the 2,4-/2,6-DNT mixture to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL) of 1.5 mg/m^3^ (OSHA 2013).

The EPA (IRIS 2002) has derived an oral reference dose (RfD) of 0.002 mg/kg/day for 2,4-DNT based on a NOAEL of 0.2 mg/kg/day for neurotoxicity, Heinz bodies, and biliary tract hyperplasia in Beagle dogs in a 2-year feeding study (Ellis et al. 1985). The EPA (IRIS 2003) also derived an oral slope factor (q1*) of 0.068 (mg/kg/day)^-1^ based on multiple tumor types in female rats (U.S. Army 1979) for the 2,4-/2,6-DNT mixture.

Tg-DNT and 3,4-DNT are on the Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) list of hazardous substances and reportable quantities and have been assigned a reportable quantity (RQ) limit of 10 pounds combined (EPA 2014d). 2,4-DNT, and 2,6-DNT also appear on the CERCLA list of chemicals and have been assigned RQ limits of 10 and 100 pounds, respectively (EPA 2014d).

The 2,4-/2,6-DNT mixture is designated as a hazardous substances under Section 311 of the Clean Water Act; any discharge of these chemicals over a specified threshold level (10 pounds) into navigable waters is subject to reporting requirements (EPA 2013d).

The international and national regulations, advisories, and guidelines regarding DNTs in air, water, and other media are summarized in Table 8-2.

Table 8-1 Oral Minimal Risk Levels (MRLs) for Dinitrotoluenes

Isomer | 2,3-DNT | 2,4-DNT | 2,5-DNT | 2,6-DNT | 3,4-DNT | 3,5-DNT
Acute-duration
MRL (mg/kg/day) | 0.09 | 0.05 | 0.007 | 0.09 | 0.03 | 0.03
Critical effect | Kidney and hematopoietic effects in rats | Neurotoxicity in dogs | Splenic lesions in rats | Hematological effects in dogs | Hematopoietic effects in rats | Testicular effects in rats
Point of departure | 275 mg/kg/day (LOAEL) | 5 mg/kg/day (NOAEL) | 2.05 mg/kg/day (BMDL_10_) | 9.31 mg/kg/day (BMDL_1SD_) | 8.05 mg/kg/day (BMDL_10_) | 10 mg/kg/day (NOAEL)
Uncertainty factor^a^ | 3,000 (10L, 10A, 10H, 3D) | 100 (10A, 10H) | 300 (10A, 10H, 3D) | 100 (10A, 10H) | 300 (10A, 10H, 3D) | 300 (10A, 10H, 3D)
Intermediate-duration
MRL (mg/kg/day) | | 0.007 | | 0.004
Critical effect | | Hematological effects in dogs | | Splenic lesions in dogs
Point of departure | | 0.67 mg/kg/day (BMDL_1SD_) | | 4 mg/kg/day (LOAEL)
Uncertainty factor^a^ | | 100 (10A, 10H) | | 1000 (10L, 10A, 10H)
Chronic-duration
MRL (mg/kg/day) | | 0.001
Critical effect | | Hematological effects in dogs
Point of departure | | 0.12 mg/kg/day (BMDL_1SD_)
Uncertainty factor^a^ | | 100 (10A, 10H)

a Uncertainty factors are comprised of uncertainty associated with use of a LOAEL (L), extrapolation from animals to humans (A), human variability (H), and/or database limitations (D).

BMDL_10_ = lower 95% confidence limit on the benchmark dose (BMD_10_) associated with a response rate that differs from the control response rate by 10%; BMDL_1SD_ = lower 95% confidence limit on the benchmark dose (BMD_1SD_) associated with a change of 1 standard deviation from the controls; DNT = dinitrotoluene; LOAEL = lowest-observed-adverse-effect-level; NOAEL = no-observed-adverse-effect level

Table 8-2 Regulations, Advisories, and Guidelines Applicable to Dinitrotoluenes

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2015
IARC | 2,4-DNT | Group 2B^a^ | IARC 2015
IARC | 2,6-DNT | Group 2B^a^ | IARC 2015
IARC | 3,5-DNT | Group 3^b^ | IARC 2015
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | No data | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2014
ACGIH | DNT^c,d^ | 0.2 mg/m^3^ | ACGIH 2014
AIHA | ERPGs | No data | AIHA 2014
DOE | PAC-1^e^ | | DOE 2012a
DOE | DNT^c^, 2,4-, 2,6-, and 3,4-DNT | 0.6 mg/m^3^ | DOE 2012a
DOE | PAC-2^e^ | | DOE 2012a
DOE | DNT^c^ | 1.1 mg/m^3^ | DOE 2012a
DOE | 2,4-DNT | 4.9 mg/m^3^ | DOE 2012a
DOE | 2,6-DNT | 12 mg/m^3^ | DOE 2012a
DOE | 3,4-DNT | 33 mg/m^3^ | DOE 2012a
DOE | PAC-3^e^ | | DOE 2012a
DOE | DNT^c^, 2,4-, 2,6-, and 3,4-DNT | 200 mg/m^3^ | DOE 2012a
EPA | AEGLs | No data | EPA 2014a
EPA | Hazardous air pollutant | | EPA 2013a; 42 USC 7412
EPA | 2,4-DNT | Yes | EPA 2013a; 42 USC 7412
EPA | NAAQS | No data | EPA 2014c
NIOSH | REL (10-hour TWA) | | NIOSH 2015
NIOSH | DNT^c,f,g^ | 1.5 mg/m^3^ | NIOSH 2015
NIOSH | IDLH | | NIOSH 2015
NIOSH | DNT^c,f,g^ | 50 mg/m^3^ | NIOSH 2015
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2013; 29 CFR 1910.1000, Table Z-1
OSHA | DNT^c,g^ | 1.5 mg/m^3^ | OSHA 2013; 29 CFR 1910.1000, Table Z-1
OSHA | PEL (8-hour TWA) for construction | | OSHA 2014a; 29 CFR 1926.55, Appendix A
OSHA | DNT^c,g^ | 1.5 mg/m^3^ | OSHA 2014a; 29 CFR 1926.55, Appendix A
OSHA | PEL (8-hour TWA) for shipyards | | OSHA 2014b; 29 CFR 1915.1000
OSHA | DNT^c,g^ | 1.5 mg/m^3^ | OSHA 2014b; 29 CFR 1915.1000
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | | EPA 2013b; 40 CFR 116.4
EPA | DNT^c^, 2,4-, 2,6-, and 3,4-DNT | Yes | EPA 2013b; 40 CFR 116.4
EPA | Drinking water standards and health advisories | | EPA 2012b
EPA | 1-day health advisory for a 10-kg child | | EPA 2012b
EPA | 2,4-DNT | 1 mg/L | EPA 2012b
EPA | 2,6-DNT | 0.4 mg/L | EPA 2012b
EPA | 10-day health advisory for a 10-kg child | | EPA 2012b
EPA | 2,4-DNT | 1 mg/L | EPA 2012b
EPA | 2,6-DNT | 0.04 mg/L | EPA 2012b
EPA | DWEL | | EPA 2012b
EPA | 2,4-DNT | 0.1 mg/L | EPA 2012b
EPA | 2,6-DNT | 0.04 mg/L | EPA 2012b
EPA | 10^-4^ Cancer risk | | EPA 2012b
EPA | 2,4-DNT | 0.005 mg/L | EPA 2012b
EPA | 2,6-DNT | 0.005 mg/L | EPA 2012b
EPA | National primary drinking water standards | No data | EPA 2009
EPA | National recommended water quality criteria: human health for the consumption of | | EPA 2013c
EPA | 2,4-DNT | | EPA 2013c
EPA | Water plus organism | 0.11 μg/L^h,i^ | EPA 2013c
EPA | Organism only | 3.4 μg/L^h,i^ | EPA 2013c
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2013d; 40 CFR 117.3
EPA | DNT | 10 pounds | EPA 2013d; 40 CFR 117.3
c. Food
FDA | EAFUS^j^ | No data | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2014
ACGIH | DNT | A3^c,k^ | ACGIH 2014
EPA | Carcinogenicity classification | | IRIS 2003
EPA | 2,4-/2,6-DNT mixture; no CASRN | B2^l^ | IRIS 2003
EPA | Oral slope factor | | IRIS 2003
EPA | 2,4-/2,6-DNT mixture; no CASRN | 0.68 (mg/kg/day)^-1^ | IRIS 2003
EPA | RfC | | IRIS 2002
EPA | 2,4-DNT | No data | IRIS 2002
EPA | RfD | | IRIS 2002
EPA | 2,4-DNT | 0.002 mg/kg/day | IRIS 2002
EPA | Identification and listing of hazardous waster | | EPA 2013e; 40 CFR 261, Appendix VIII
EPA | 2,4-DNT | U105 | EPA 2013e; 40 CFR 261, Appendix VIII
EPA | 2,6-DNT | U106 | EPA 2013e; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products | No data | EPA 2014c
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity | | EPA 2014d 40 CFR 302.4
EPA | DNT^c^ and 3,4-DNT | 10 pounds^m^ | EPA 2014d 40 CFR 302.4
EPA | 2,4-DNT | 10 pounds^n^ | EPA 2014d 40 CFR 302.4
EPA | 2,6-DNT | 100 pounds^o^ | EPA 2014d 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | | EPA 2014e; 40 CFR 372.65
EPA | DNT | 01/01/1990 | EPA 2014e; 40 CFR 372.65
EPA | 2,4-DNT | 01/01/1987 | EPA 2014e; 40 CFR 372.65
EPA | 2,6-DNT | 01/01/1987 | EPA 2014e; 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2014f; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | | EPA 2014f; 40 CFR 712.30
EPA | 2,4-DNT | | EPA 2014f; 40 CFR 712.30
EPA | Effective date | 03/11/1994 | EPA 2014f; 40 CFR 712.30
EPA | Reporting date | 05/10/1994 | EPA 2014f; 40 CFR 712.30
EPA | TSCA health and safety data reporting | | EPA 2014g; 40 CFR 716.120
EPA | 2,4-DNT | | EPA 2014g; 40 CFR 716.120
EPA | Effective date | 03/11/1994 | EPA 2014g; 40 CFR 716.120
EPA | Reporting date | 06/30/1998 | EPA 2014g; 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2014

a Group 2B: possibly carcinogenic to humans.

b Group 3: not classifiable as to its carcinogenicity to humans

c Tg-DNT is composed primarily of the 2,4- and 2,6-DNT isomers and the other four isomers (2,3-, 2,5-, 3,4-, and 3,5-DNT) make up only 5% of Tg-DNT.

d Skin: refers to the potential significant contribution to the overall exposure by the cutaneous route.

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2012b).

f NIOSH potential occupational carcinogen.

g Skin designation.

h This criterion is based on carcinogenicity of 10^-6^ risk.

i EPA has updated its national recommended water quality criteria for human health. The comment period for the draft water quality criteria ended August 13, 2014. A final update has not been issued yet, but the proposed criteria for 2,4-DNT is 0.0378 μg/L for water + organism and 0.711 μg/L for organism only (EPA 2014b).

j The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

k A3: confirmed animal carcinogen with unknown relevance to humans.

l Group B2: probable human carcinogen.

m Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and Section 307(a) of the Clean Water Act.

n Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and Section 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

o Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and Section 307(a) of the Clean Water Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DNT = dinitrotoluene; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; WHO = World Health Organization