# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of the individual isomers of DNT is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of the individual isomers of DNT is located in Table 4-2. Data regarding specific isomers of DNT have been provided whenever possible. The isomers of DNT have many similar traits, including identical molecular weights, but also have distinguishable qualities. For instance, 2,4-DNT has higher melting and boiling points and a greater solubility in water than 2,6-DNT (HSDB 2012).

DNTs are generally produced as a technical-grade mixture, which consists of approximately 76.5% 2,4-DNT and 18.8% 2,6-DNT. The remaining ~5% consists of other isomers of DNT and minor contaminants such as TNT and the mononitrotoluenes (HSDB 2012). Unspecified forms of DNT (DNT not otherwise specified or NOS) can be characterized under the CAS Registry Number of 25321-14-6. Where information pertains to Tg-DNT or DNT NOS, it has been so noted.

Table 4-1 Chemical Identity of Dinitrotoluenes

Characteristic | Information^a^
Chemical name | 2,3-Dinitrotoluene | 2,4-Dinitrotoluene | 2,5-Dinitrotoluene
Synonym(s) | 1-Methyl-2,3-dinitrobenzene; 2,3-DNT | 1-Methyl-2,4-dinitrobenzene; 2,4-dinitrotoluol; 2,4-DNT | 2-Methyl-1,4-dinitrobenzene; 2,5-DNT
Registered trade name(s) | No data | No data | No data
Chemical formula | C_7_H_6_N_2_O_4_ | C_7_H_6_N_2_O_4_ | C_7_H_6_N_2_O_4_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 602-01-7 | 121-14-2 | 619-15-8
NIOSH RTECS | XT1400000 | XT1575000 | XT1750000
EPA hazardous waste
| No data | U105 | No data
OHM/TADS | | 7800118
DOT/UN/NA/IMDG shipping | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid) | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid) | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid)
HSDB | 5499 | 1144 | 5504
NCI | No data | NCI-C01865 | No data

Characteristic | Information^a^
Chemical name | 2,6-Dinitrotoluene | 3,4-Dinitrotoluene | 3,5-Dinitrotoluene
Synonym(s) | 1-Methyl-2,6-dinitrotoluene; 2,6-DNT | 4-Methyl-1,2-Dinitrobenzene; 3,4-DNT | 1-methyl-3,5-dinitrobenzene; 3,5-DNT
Registered trade name(s) | No data | No data | No data
Chemical formula | C_7_H_6_N_2_O_4_ | C_7_H_6_N_2_O_4_ | C_7_H_6_N_2_O_4_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 606-20-2 | 610-39-9 | 618-85-9
NIOSH RTECS | XT1925000 | XT2100000 | XT2150000
EPA hazardous waste
| U106 | No data | No data
OHM/TADS | 8300219
DOT/UN/NA/IMDG shipping | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid) | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid) | IMO 6.1; UN 1600 (molten); UN 2038 (solid or liquid)
HSDB | 2931 | 5501 | 6463
NCI | No data | No data | No data

a All information obtained from HSDB 2012

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Dinitrotoluenes

Property | Information^a^
Chemical name | 2,3-Dinitrotoluene | 2,4-Dinitrotoluene | 2,5-Dinitrotoluene
Molecular weight | 182.14 | 182.14 | 182.14
Color | Yellow | Yellow | No data
Physical state | Solid | Solid | Solid
Melting point | 59–61 °C | 71 °C | 52.5 °C
Boiling point | 284 °C^b^ | 300 °C (slight decomposition) | 284 °C^b^
Density | No data | 1.3208 (71 °C) | 1.282 (111 °C)
Odor | No data | Slight | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 220 mg/L (25 °C, estimated)^b^ | 270 mg/L (22 °C) | 220 mg/L (25 °C, estimated)^b^
Organic solvents | No data | Soluble in acetone, alcohol, benzene, ethanol, diethyl ether, pyridine, carbon disulfide | Soluble in ethanol; very soluble in carbon disulfide
Partition coefficients:
Log K_ow_ | 2.18 (estimated)^b^ | 1.98 | 2.18 (estimated)^b^
Log K_oc_ | No data | 2.56^c^ | No data
Vapor pressure at 20 °C | 3.97x10^-4^ torr (estimated)^d^ | 1.4x10^-4^ torr | 3.97x10^-4^ torr (estimated)^d^
Henry’s law constant at 25 °C Autoignition temperature | 9.26x10^-8^ atm-m^3^/mol (estimated)^b^ | 5.4x10^-8^ atm-m^3^/mol^e^ | 9.26x10^-8^ atm-m^3^/mol (estimated)^b^
Flashpoint
Flammability limits | No data | No data | No data
Conversion factors | No data | 404 °F | 404 °F
| No data | No data | No data
Explosive limits | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm

Property | Information^a^
Chemical name | 2,6-Dinitrotoluene | 3,4-Dinitrotoluene | 3,5-Dinitrotoluene
Molecular weight | 182.14 | 182.14 | 182.14
Color | Yellow to red | Red | Yellow to red
Physical state | Solid | Solid | Solid
Melting point | 66 °C | 58.3 °C | 93 °C
Boiling point | 285 °C | 284 | 315 °C^b^
Density | 1.2833 (111 °C) | 1.2594 (111 °C) | 1.2772 (111 °C)
Odor | Slight | Slight | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 180 mg/L (20 °C) | 100 mg/L (25 °C)^f^ | 145 mg/L (25 °C)
Organic solvents | Soluble in ethanol, chloroform | Soluble in ethanol and carbon disulfide; slightly soluble in chloroform | Soluble in benzene, ethyl ether, ethanol, chloroform, carbon disulfide
Partition coefficients:
Log K_ow_ | 2.10 | 2.08^g^ | 2.18 (estimated)^b^
Log K_oc_ | No data | No data | No data
Vapor pressure at 20 °C | 5.67x10^-4^ torr | 3.97x10^-4^ torr (estimated)^d^ | 4.05x10^-4^ torr^h^
Henry’s law constant at 25 °C
Autoignition temperature | 7.47x10^-7^ atm-m^3^/mol (estimated)^b^ | 9.26x10^-8^ atm-m^3^/mol (estimated)^b^ | 9.26x10^-8^ atm-m^3^/mol (estimated)^b^
Flashpoint
Flammability limits | No data | No data | No data
Conversion factors | 404 °F | 404 °F | No data
| No data | No data | No data
Explosive limits | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm | 1 ppm=7.40 mg/m^3^; 1 mg/m^3^=0.13 ppm

a All information obtained from HSDB 2012 unless otherwise stated.

b EPA 2011

c U.S. Army 1980

d Neely and Blau 1985

e Altschuh et al. 1999

f Chemicals Inspection Testing Institute 1992

g Nakagawa et al. 1992

h AIChE 1992