# CHAPTER 8 REFERENCES

Alber M, Bîhm HB, Brodesser J, 1989. Determination of nitrophenols in rain and snow. Fresenius Z Anal Chem 334:540–545. 10.1007/BF00483573.
Ames BN, Kammen HO, Yamasaki E. 1975. Hair dyes are mutagenic: identification of a variety of mutagenic ingredients. Proc Natl Acad Sci U S A 72(6):2423–2427. 10.1073/pnas.72.6.2423.1094469
Anderson D, Styles JA. 1978. The bacterial mutation test. Six tests for carcinogenicity. Br J Cancer 37(6):924–930. 10.1038/bjc.1978.134.354673
Anderson HH, Reed AC, Emerson GA. 1933. Toxicity of alpha-dinitrophenol. Report of case. J Am Med Assoc 101(14):552–560. 10.1001/jama.1933.02740390011003.
Anderson BE, Zeiger E, Shelby MD, 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16 Suppl 18:55–137. 10.1002/em.2850160505.
Arnold L, Collins C, Starmer GA. 1976. Studies on the modification of renal lesions due to aspirin and oxyphenbutazone in the rat and the effects on the kidney of 2,4-dinitrophenol. Pathology 8(3):179–184. 10.3109/00313027609058995.1004943
Asman WA, Jorgensen A, Bossi R, 2005. Wet deposition of pesticides and nitrophenols at two sites in Denmark: Measurements and contributions from regional sources. Chemosphere 59(7):1023–1031. 10.1016/j.chemosphere.2004.11.048.15823336
Atkinson R. 1988. Estimation of gas-phase hydroxyl radical rate constants for organic chemicals. Environ Toxicol Chem 7:435–442.
Atkinson R, Aschmann SM, Arey J. 1992. Reactions of OH and NO_3_ radicals with phenol, cresols, and 2-nitrophenyl at 296 ± 2 K. Environ Sci Technol 26(7):1397–1403. 10.1021/es00031a018.
ATSDR. 1988. Health assessment for Ritari Post and Pole Site, Sebeka, Minnesota Region 5. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS No. MND980904064.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 2019. Dinitrophenols. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Bakke JL, Lawrence N. 1965. Effect of dinitrophenol on pituitary-thyroid activity in the rat. Endocrinology 77(2):382–389. 10.1210/endo-77-2-382.5836175
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bartha R, Lanzilotta RP, Pramer D. 1967. Stability and effect of some pesticides in soil. Appl Microbiol 5:67–75.
Bartlett J, Brunner M, Gough K. 2010. Deliberate poisoning with dinitrophenol (DNP): an unlicensed weight loss pill. Emerg Med J 27(2):159–160. 10.1136/emj.2008.069401.20156878
Battersby NS, Wilson V. 1989. Survey of the anaerobic biodegradation potential of organic chemicals in digesting sludge. Appl Environ Microbiol 55(2):433–439. 10.1128/AEM.55.2.433-439.1989.16347851
Bayer LM, Gray H. 1935. Obesity treatment by diet, thyroid and dinitrophenol: Result on 106 outpatients. Am J Med Sci 189:86–91.
Beinhauer LG. 1934. Urticaria following the use of dinitrophenol. WV Med J October:446–447.
Bettman JW. 1946. Experimental dinitrophenol cataract. Am J Ophthalmol 29(11):1388–1395. 10.1016/0002-9394(46)92034-x.20276973
Boardman WW. 1935. Rapidly developing cataract after dinitrophenol. J Am Med Assoc 105(2):108. 10.1001/jama.1935.02760280020007.
Bohm HB, Feltes J, Volmer D, 1989. Identification of nitrophenols in rainwater by high- performance liquid chromatography with photodiode array detection. J Chromatogr 478:399–407.
Boopathy R, Kulpa CF. 1993. Nitroaromatic compounds serve as nitrogen source for Desulfovibrio sp. (B strain). Can J Microbiol 39(4):430–433. 10.1139/m93-062.8500012
Booth G. 1991. Nitro compounds, aromatic. In: Elvers B, ed. Ullmann’s encyclopedia of industrial chemistry. Vol. A17. New York, NY: VCH Publishers, 411, 418.
Bortz EL. 1934. Metabolic stimulants with particular reference to sodium dinitrophenol. Ann Intern Med 8(5):599. 10.7326/0003-4819-8-5-599.
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19(4):413–424.13652126
Britt BA. 1979. Etiology and pathophysiology of malignant hyperthermia. Fed Proc 38(1):44–48.759238
Brody TM. 1956. Action of sodium salicylate and related compounds on tissue metabolism in vitro. J Pharmacol Exp Ther 117(1):39–51.13320299
Brown SC, Grady CPL, Tabak HH. 1990. Biodegradation kinetics of substituted phenolics: demonstration of a protocol based on electrolytic respirometry. Water Res 24(7):853–861. 10.1016/0043-1354(90)90135-s.
Bruhn C, Lenke H, Knackmuss HJ. 1987. Nitrosubstituted aromatic compounds as nitrogen source for bacteria. Appl Environ Micro 53:208–210.
Budavari S, O’Neil MJ, Smith A, 1989. Dinitrophenols. In: The Merck index. 11^th^ ed. Rahway, NJ: Merck & Co., Inc., 321, 977.
Bunai Y, Akaza K, Nagai A. 2012. Hyperthermia: Pathological findings and recognition at forensic autopsies. In: Gao X, Chen H, eds. Hyperthermia: Recognition prevention and treatment. Hauppauge, NY: Nova Science Publishers, Inc., 209–214.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Burke JF, Whitehouse MW. 1967. Concerning the differences in uncoupling activity of isomeric dinitrophenols. Biochem Pharmacol 16(1):209–211. 10.1016/0006-2952(67)90201-8.
Burnett C, Loehr R, Corbett J. 1977. Dominant lethal mutagenicity study on hair dyes. J Toxicol Environ Health 2(3):657–662. 10.1080/15287397709529467.846013
Buschke W. 1947. Acute reversible cataract in chickens due to various nitrocompounds. Am J Ophthalmol 30:1356–1368.20269945
Cairns R, Raubenheimer J, Brown JA, 2020. 2,4-Dinitrophenol exposures and deaths in Australia after the 2017 up-scheduling. Med J Aust 212(9):434–434.e431. 10.5694/mja2.50528.
Caldeira da Silva CC, Cerqueira FM, Barbosa LF, 2008. Mild mitochondrial uncoupling in mice affects energy metabolism, redox balance and longevity. Aging Cell 7(4):552–560. 10.1111/j.1474-9726.2008.00407.x.18505478
Capel PD, Leuenberger C, Giger W. 1991. Hydrophobic organic chemicals in urban fog. Atmos Environ 25(7):1335–1346. 10.1016/0960-1686(91)90244-2.
Castor CW, Beierwaltes W. 1956. Effect of 2,4-dinitrophenol on thyroid function in man. J Clin Endocrinol Metab 16(8):1026–1031. 10.1210/jcem-16-8-1026.13345860
Ceylan Z, Sisman T, Yazici Z, 2016. Embryotoxicity of nitrophenols to the early life stages of zebrafish (Danio rerio). Toxicol Ind Health 32(8):1414–1422. 10.1177/0748233714562444.25552538
Chambers CW, Tabak HH, Kabler PW. 1963. Degradation of aromatic compounds by phenol-adapted bacteria. J Water Pollut Contr Fed 35:1517–1528.
ChemID. 1992. On-line database. 881. National Library of Medicine.
Chiu CW, Lee LH, Wang CY, 1978. Mutagenicity of some commercially available nitro compounds for Salmonella typhimurium. Mutat Res Genet Toxicol 58(1):11–22. 10.1016/0165-1218(78)90090-3.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Couet C, Jan P, Debry G. 1991. Lactose and cataract in humans: a review. J Am Coll Nutr 10(1):79–86. 10.1080/07315724.1991.10718130.1901325
Coulter KE, Kehde H, Hiscock BF. 1969. Styrene. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 19. 2^nd^ ed. New York, NY: John Wiley & Sons, Inc., 55–85.
Cutting WC, Tainter ML. 1933. Metabolic actions of dinitrophenols with the use of balanced and unbalanced diets. J Am Med Assoc 27:2099–2102.
Cutting WC, Mehrtens HG, Tainter ML. 1933. Actions and uses of dinitrophenol. J Am Med Assoc 101:193–195.
Cutting WC, Rytand DA, Tainter ML. 1934. Relationship between blood cholesterol and increased metabolism from dinitrophenol and thyroid. J Clin Invest 13:547–552.16694228
Dameshek W, Gargill SL. 1934. Studies in agranulocytosis. IV. Report of two cases of agranulocytosis following the use of dinitrophenol. N Engl J Med 211(10):440–443.
Davidson EN, Shapiro M. 1934. Neutropenia following dinitrophenol, with improvement after pentnucleotide and leukocyte cream. J Am Med Assoc 103(7):480. 10.1001/jama.1934.72750330001008a.
De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2(4):283–298. 10.1093/carcin/2.4.283.7023727
Delhomme O, Morville S, Millet M. 2010. Seasonal and diurnal variations of atmospheric concentrations of phenols and nitrophenols measured in the Strasbourg area, France. Atmos Pollut Res 1(1):16–22. 10.5094/apr.2010.003.
Demerec M, Bertani G, Gibson JE. 1951. A survey of chemicals for mutagenic action on E. coli. Am Nat 85:119–136.
DeWalle FB, Kalman DA, Dills R, 1982. Presence of phenolic compounds in sewage effluent and sludge from municipal sewage treatment plants. Water Sci Technol 14(4–5):143–150. 10.2166/wst.1982.0094.
Dintenfass H. 1934. An ear complication from dinitrophenol medication. J Am Med Assoc 102:2193–2195. 10.1001/jama.1934.62750110001011.
Divakaruni AS, Brand MD. 2011. The regulation and physiology of mitochondrial proton leak. Physiology 26:192–205.21670165
DOE. 1986. Toxic organic chemicals in waste streams: Anaerobic bioconversion to methane. Washington, DC: Department of Energy. DE86009496.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Dominguez SE, Menkel JL, Fairbrother A, 1993. The effect of 2,4-dinitrophenol on the metabolic rate of bobwhite quail. Toxicol Appl Pharmacol 123(2):226–233. 10.1006/taap.1993.1241.8248930
Dow Chemical Co. 1940. Initial 8e submission: Toxicity and health hazards of 2,4-dinitrophenol, dinitro-ortho-cresol, and dinitro-ortho-cyclohexyl phenol (final report) with letter dated 3/18/92 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8e. OTS0536148. 88-920001472S. 8EHQ-0392-2830S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0536145.xhtml. October 1, 2020.
Dow Chemical Co. 1950. Initial 8e submission: The comparative acute oral toxicity of several dinitrophenols used in agriculture (final report) with cover letter dated 3/18/92 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8e. OTS0536145. 88-920001469S. 8EHQ-0392-2827S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0536145.xhtml#. October 1, 2020.
Duflou J. 2019. A case of fatal 2,4-dinitrophenol (2,4-DNP) intoxication with delayed onset methaemoglobinaemia. Pathology 51(5):548–549. 10.1016/j.pathol.2019.03.006.31221434
Dunlop DM. 1934. The use of 2:4-dinitrophenol as a metabolic stimulant. Br Med J 1(3820):524–527.20778151
Dybing E, Thorgeirsson SS. 1977. Metabolic activation of 2,4-diaminoanisole, a hair-dye component-I: Role of cytochrome P-450 metabolism in mutagenicity in vitro. Biochem Pharmacol 26(8):729–734. 10.1016/0006-2952(77)90216-7.856205
Eichert H. 1936. An unusual case of dinitrophenol poisoning. Bull Johns Hopkins Hosp 63:378–381.
Eiseman JL, Gehring PJ, Gibson JE. 1972. The in vitro metabolism of 2,4-dinitrophenol by rat liver homogenates. Toxicol Appl Pharmacol 21(2):275–285. 10.1016/0041-008x(72)90071-3.4401924
Eiseman JL, Gehring PJ, Gibson JE. 1974. Kinetics of in vitro nitro reduction of 2,4-dinitrophenol by rat liver homogenates. Toxicol Appl Pharmacol 27(1):140–144. 10.1016/0041-008x(74)90181-1.4852620
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Eli Lilly & Co. 1992. Initial submission: Letter from Eli Lilly & Company to US EPA submitting results on dinitrophenol. I. Acute rat oral study with attachments (sanitized). Eli Lilly & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8e. OTS0543650.
Ellenhorn MJ, Barceloux DG. 1988. Anticholinergics. In: Medical toxicology: Diagnosis and treatment of human poisoning. Amsterdam, Netherlands: 1096–1097.
England P, Harland WA, Orr JS, 1973. Increased thyroxine secretion following administration of dinitrophenol to rats. J Physiol 229(1):33–40. 10.1113/jphysiol.1973.sp010124.4689979
EPA. 1979a. Water-related environmental fate of 129 priority pollutants. Washington, DC: U.S. Environmental Protection Agency. Vol. II. EPA440479029B. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000K6JL.txt. October 1, 2020.
EPA. 1979b. Biodegradation and treatability of specific pollutants. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600979034. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300065S9.txt. October 1, 2020.
EPA. 1981. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. October 1, 2020.
EPA. 1986a. Part 403. General pretreatment regulations for existing and new sources of pollution. U.S. Environmental Protection Agency. Fed Regist 51(83):16030–16031.
EPA. 1986b. Method 8040: Phenols by gas chromatography. Test methods for evaluation solid waste. Volume IB: Laboratory manual physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency. SW846. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100Q39V.txt. December 14, 2020.
EPA. 1986c. Method 8270: Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique. Test methods for evaluation solid waste. Volume IB: Laboratory manual physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency. SW846. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100Q39V.txt. December 14, 2020.
EPA. 1988a. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600687008. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=34855. September 30, 2020.
EPA. 1988b. Superfund record of decision (EPA Region 2): Lipari landfill, Mantau Township, Gloucester County, New Jersey, July 11, 1988. Third remedial action. Washington, DC: U.S. Environmental Protection Agency. PB89219224. EPARODR0288074. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB89219224.xhtml. October 1, 2020.
EPA. 1988c. 268.41. Treatment standards expressed as waste concentrations. U.S. Environmental Protection Agency. Fed Regist 53(68):11789–11791.
EPA. 1989. Treatability potential for EPA listed hazardous wastes in soil. Ada, OK: U.S. Environmental Protection Agency. EPA600389011. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=200095E5.txt. October 1, 2020.
EPA. 1990. 268.43 (a). Treatment standards expressed as waste concentrations. U.S. Environmental Protection Agency. Fed Regist 55(106):22701–22713.
EPA. 1991. Twenty-seventh report of the Interagency Testing Committee to the Administrator, receipt of report and request for comments regarding priority list of chemicals: 2,6-Dinitrophenol. U.S. Environmental Protection Agency. Fed Regist (56):9564. https://www.loc.gov/item/fr056044/. October 1, 2020.
EPA. 1992. Part 266. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. U.S. Environmental Protection Agency. Fed Regist 57(165):38564–38566.
EPA. 1993. Part 258. Criteria for municipal solid waste landfills. U.S. Environmental Protection Agency. Fed Regist 58(143):40578–40579.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. October 1, 2020.
EPA. 2007. Provisional peer-reviewed toxicity values for 2,4-dinitrophenol. Washington, DC: U.S. Environmental Protection Agency. EPA690R07017F. https://cfpub.epa.gov/ncea/pprtv/documents/Dinitrophenol24.pdf. September 29, 2020.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
Epstein EE, Rosenblum H. 1935. Peripheral neuritis and abortion following dinitrophenol therapy: Report of a case. J Lab Clin Med 20:1118–1121.
Eriksson CJ, Lindros KO, Forsander OA. 1974. 2,4-Dinitrophenol-induced increase in ethanol and acetaldehyde oxidation in the perfused rat liver. Biochem Pharmacol 23(15):2193–2195. 10.1016/0006-2952(74)90587-5.4416928
Escher BI, Hunziker R, Schwarzenbach RP. 1999. Kinetic model to describe the intrinsic uncoupling activity of substituted phenols in energy transducing membranes. Environ Sci Technol 33(4):560–570. 10.1021/es980545h.
FDA. 2016. FDA targets unlawful internet sales of illegal prescription medicines during International Operation Pangea IX. U.S. Food and Drug Administration. https://www.fda.gov/news-events/press-announcements/fda-targets-unlawful-internet-sales-illegal-prescription-medicines-during-international-operation. May 21, 2021.
FDA. 2020a. Texas woman charged with selling misbranded drug. U.S. Food and Drug Administration. https://www.fda.gov/inspections-compliance-enforcement-and-criminal-investigations/press-releases/texas-woman-charged-selling-misbranded-drug. May 21, 2021.
FDA. 2020b. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Flower RJ, Moncada S, Vane JR. 1985. Analgesic-antipyretics and anti-inflammatory agents; drugs employed in the treatment of gout. In: Gilman AG, Goodman LS, Rall TW, eds. Goodman and Gilman’s the pharmacological basis of therapeutics. 7^th^ ed. New York NY: Macmillan Publishing Co., 674–715.
Fouts JR, Brodie BB. 1957. The enzymatic reduction of chloramphenicol, p-nitrobenzoic acid and other aromatic nitro compounds in mammals. J Pharmacol Exp Ther 119(2):197–207.13417069
Friedman MA, Staub J. 1976. Inhibition of mouse testicular DNA synthesis by mutagens and carcinogens as a potential simple mammalian assay for mutagenesis. Mutat Res 37(1):67–76. 10.1016/0027-5107(76)90055-5.967187
Games LM, Hites RA. 1977. Composition, treatment efficiency, and environmental significance of dye manufacturing plant effluents. Am J Physiol 49(9):1433–1440. 10.1021/ac50017a035.
Garner RC, Nutman CA. 1977. Testing of some azo dyes and their reduction products for mutagenicity using Salmonella typhimurium TA1538. Mutat Res 44:9–19.331098
Garrett NE, Lewtas J. 1983. Cellular toxicity in Chinese hamster ovary cell cultures. I. Environ Res 32(3):455–465. 10.1016/0013-9351(83)90125-1.6641673
Gatz EE, Jones JR. 1972. Haloperidol antagonism to the hypermetabolic effects of 2,4-dinitrophenol (in vitro to in vivo correlation). In: Fink BR, ed. Cellular biology and toxicity of anesthetics. Baltimore, MD: Williams and Wilkins Co., 304–311.
Gautschi JR, Kern RM, Painter RB. 1973. Modification of replicon operation in HeLa cells by 2,4-dinitrophenol. J Mol Biol 80(3):393–403. 10.1016/0022-2836(73)90411-7.4762560
Gehring PJ, Buerge JF. 1969a. The cataractogenic activity of 2,4-dinitrophenol in ducks and rabbits. Toxicol Appl Pharmacol 14(3):475–486. 10.1016/0041-008x(69)90009-x.5787516
Gehring PJ, Buerge JF. 1969b. The distribution of 2,4-dinitrophenol relative to its cataractogenic activity in ducklings and rabbits. Toxicol Appl Pharmacol 15(3):574–592. 10.1016/0041-008x(69)90060-x.5353822
Geiger JC. 1933. A death from alpha-dinitrophenol poisoning. J Am Med Assoc 101(17):1333–1333. 10.1001/jama.1933.02740420053027.
Ghosh S, Paweletz N, Armas-Portela R. 1989. Post-metaphase mitotic events in cells treated with dinitrophenol. Indian J Exp Biol 27(4):317–323.2807412
Gibson JE. 1973. Teratology studies in mice with 2-sec-butyl-4,6-dinitrophenol (dinoseb). Food Cosmet Toxicol 11:31–43.4716128
Gier MJ, Hess TF, Howe B, 1989. Comparative studies of biodegradation kinetics dynamics of populations mineralizing 2,4-dinitrophenol in pure cultures and in soil. In: 89th Annual Meeting of the American Society for Microbiology, New Orleans, LA, May 14–18, 1989. Washington, DC: American Society for Microbiology, 351.
Gisclard JB, Woodward MM. 1946. 2,4-Dinitrophenol poisoning; a case report. J Ind Hyg Toxicol 28:47–51.21017133
Goldgof M, Xiao C, Chanturiya T, 2014. The chemical uncoupler 2,4-dinitrophenol (DNP) protects against diet-induced obesity and improves energy homeostasis in mice at thermoneutrality. J Biol Chem 289(28):19341–19350. 10.1074/jbc.M114.568204.24872412
Goldman A, Haber M. 1936. Acute complete granulopenia with death due to dinitrophenol poisoning. J Am Med Assoc 107(26):2115–2117. 10.1001/jama.1936.02770520017005.
Goldman AS, Yakovac WC. 1964. Salicylate intoxication and congenital anomalies. Arch Environ Health 8:648–656.14120561
Grant LF, Schube PG. 1934. The effect of alpha dinitrophenol (1-2-4) on blood cholesterol in man. J Lab Clin Med 20:56–60.
Grosjean D. 1985. Reactions of o-cresol and nitrocresol with NOX in sunlight and with ozone-nitrogen dioxide mixtures in the dark. Environ Sci Technol 19:968–974.
Grundlingh J, Dargan PI, El-Zanfaly M, 2011. 2,4-dinitrophenol (DNP): a weight loss agent with significant acute toxicity and risk of death. J Med Toxicol 7(3):205–212. 10.1007/s13181-011-0162-6.21739343
Gundersen K, Jensen HL. 1956. A soil bacterium decomposing organic nitro-compounds. Acta Agric Scand 6(1):100–114. 10.1080/00015125609434235.
Haasio K, Lounatmaa K, Sukura A. 2002a. Entacapone does not induce conformational changes in liver mitochondria or skeletal muscle in vivo. Exp Toxicol Pathol 54(1):9–14. 10.1078/0940-2993-00228.12180806
Haasio K, Nissinen E, Sopanen L, 2002b. Different toxicological profile of two COMT inhibitors in vivo: The role of uncoupling effects. J Neural Transm (Vienna) 109(11):1391–1401. 10.1007/s00702-002-0748-x.12454735
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2^nd^ ed. Philadelphia, PA: WB Saunders Co., 1079–1081.
Hansch C, Leo AJ. 1985. Medchem project issue No. 26. Claremont, CA: Pomona College.
Harvey DG. 1959. On the metabolism of some aromatic nitro compounds by different species of animal. III. The toxicity of the dinitrophenols, with a note on the effects of high environmental temperatures. J Pharm Pharmacol 11:462–474. 10.1111/j.2042-7158.1959.tb12583.x.14400214
Hawley GG. 1981. Dinitrophenols. In: The condensed chemical dictionary. 10^th^ ed. New York, NY: Van Nostrand Reinhold Co., 375.
Hayes WJ. 1982. 2,4-Dinitroanisole. Pesticides studied in man. Baltimore, MD: The Williams and Wilkins Co.
Heinemann B, Howard AJ. 1964. Induction of lambda-bacterial phage in Escherichia coli as a screening test for potential antitumor agents. Appl Microbiol 12:234–239.14170962
Hess TF, Schmidt SK, Silverstein J, 1990. Supplemental substrate enhancement of 2,4-dinitrophenol mineralization by a bacterial consortium. Appl Environ Microbiol 56(6):1551–1558. 10.1128/AEM.56.6.1551-1558.1990.16348203
Hessing EE. 1937. Cataract due to dinitrophenol. Arch Ophthalmol 17:513–515.
Hightower KR, Reddy VN. 1981. Metabolic studies on calcium transport in mammalian lens. Curr Eye Res 1(4):197–204. 10.3109/02713688109001849.7333123
Hill HE. 1936. Cataract formation following use of dinitrophenol. J Indiana State Med Assoc 26:67–69.
Hilliard CA, Armstrong MJ, Bradt CI, 1998. Chromosome aberrations in vitro related to cytotoxicity of nonmutagenic chemicals and metabolic poisons. Environ Mol Mutagen 31(4):316–326.9654240
Hilton J, Walker MD. 1977. DNA strand scission and its repair following exposure of cells to inhibitors of oxidative phosphorylation. Biochem Biophys Res Commun 75(4):909–914. 10.1016/0006-291x(77)91468-1.558757
Hinkel M, Reischl A, Schramm KW, 1989. Concentration levels of nitrated phenols in conifer needles. Chemosphere 18:2433–2439.
Hitch JM, Schwartz WF. 1936. Late toxic results, including dermatitis exfoliative, from “Slim” (dinitrophenol). J Am Med Assoc 106:2130–2132.
Hoffman AM, Butt EM, Hickey NG. 1934. Neutropenia following aminopyrine. J Am Med Assoc 102:1213–1214.
Holborow A, Purnell RM, Wong JF. 2016. Beware the yellow slimming pill: fatal 2,4-dinitrophenol overdose. BMJ case reports 2016:1–3. 10.1136/bcr-2016-214689.
Horner WD. 1942. Dinitrophenol and its relation to formation of cataracts. Arch Ophthalmol 27:1097–1121.
Horner WD, Jones RB, Boardman WW. 1935. Cataracts following dinitrophenol: Preliminary report of three cases. J Am Med Assoc 105:108–110.
HSDB. 1994. Hazardous Substances Data Bank. Silver platter version. August 1994. Bethesda, MD: National Library of Medicine.
Hsiao AL, Santucci KA, Seo-Mayer P, 2005. Pediatric fatality following ingestion of dinitrophenol: postmortem identification of a “dietary supplement”. Clin Toxicol 43(4):281–285.
Huang Q, Wang L, Han S. 1995. The genotoxicity of substituted nitrobenzenes and the quantitative structure-activity relationship studies. Chemosphere 30(5):915–923.7712138
Huang QG, Kong LR, Liu YB, 1996. Relationships between molecular structure and chromosomal aberrations in in vitro human lymphocytes induced by substituted nitrobenzenes. Bull Environ Contam Toxicol 57(3):349–353. 10.1007/s001289900197.8672058
Hudman D, Rainbow RD, Lawrence CL, 2002. The origin of calcium overload in rat cardiac myocytes following metabolic inhibition with 2,4-dinitrophenol. J Mol Cell Cardiol 34(7):859–871. 10.1006/jmcc.2002.2024.12099724
Hudson-Baruth BA, Seitz MG. 1986. Adsorption of select phenol derivatives by dolomite. Environ Pollut 11(1):15–28. 10.1016/0143-148x(86)90029-7.
Hunt WD. 1934. Dinitrophenol: Clinical experience. Northwest Med 33:209–212.
IARC. 1993a. IARC Monographs on the evaluation of the carcinogenicity risk of chemicals to humans: 2-Amino-4-nitrophenol. International Agency for Research on Cancer. Vol. 57, 167–176. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono57.pdf. October 1, 2020.
IARC. 1993b. IARC Monographs on the evaluation of the carcinogenicity risk of chemicals to humans: 2-Amino-5-nitrophenol. International Agency for Research on Cancer. Vol. 57, 177–184. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono57.pdf. October 1, 2020.
IARC. 2020. Agents classified by the IARC Monographs, Volumes 1-125. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. April 30, 2020.
Ilivicky J, Casida JE. 1969. Uncoupling action of 2,4-dinitrophenols, 2-trifluoromethylbenzimidazoles and certain other pesticide chemicals upon mitochondria from different sources and its relation to toxicity. Biochem Pharmacol 18(6):1389–1401. 10.1016/0006-2952(69)90252-4.5799112
Imerman SWICP. 1936. Dinitrophenol poisoning with thrombocytopenia, granulopenia, anemia and purpura complicated by lung abscess. J Am Med Assoc 105(1):9–14. 10.1001/jama.1936.02770130035011.
IRIS. 2005. 2,4-Dinitrophenol. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0152_summary.pdf. November 21, 2017.
Israel Y, Khanna JM, Lin R. 1970. Effect of 2,4-dinitrophenol on the rate of ethanol elimination in the rat in vivo. Biochem J 120(2):447–448. 10.1042/bj1200447.4321897
James RH, Adams RE, Finkel JM, 1984. Evaluation of analytical methods for the determination of POHC in combustion products. In: Proceedings of the 77th Air Pollution Control Association annual meeting. San Francisco, CA: Air Pollution Control Association, Paper 84-18.85, 81-25.
Jensen HL, Gundersen K. 1955. Biological decomposition of aromatic nitro-compounds. Nature 175(4451):341. 10.1038/175341a0.13235894
Jiang J, Yuan Z, Huang W, 2011. 2, 4-dinitrophenol poisoning caused by non-oral exposure. Toxicol Ind Health 27(4):323–327. 10.1177/0748233710387004.21177364
Jiang JK, Fang W, Gu LH, 2016. Early changes of peripheral blood lymphocyte subpopulations in patients with occupational 2,4-dinitrophenol poisoning. Biomed Environ Sci 29(12):909–914. 10.3967/bes2016.122.28081753
Juchau MR, Krasner J, Yaffe SJ. 1970. Model systems for aromatic nitro group reduction-relationships to tissue catalyzed reagents. Biochem Pharmacol 19(2):443–455. 10.1016/0006-2952(70)90200-5.4396247
Jung J, Ishida K, Nishihara T. 2004. Anti-estrogenic activity of fifty chemicals evaluated by in vitro assays. Life Sci 74(25):3065–3074. 10.1016/j.lfs.2003.10.030.15081572
Kaiser JA. 1964. Studies on the toxicity of disophenol (2,6-diiodo-4-nitrophenol) to dogs and rodents plus some comparisons with 2,4-dinitrophenol. Toxicol Appl Pharmacol 6:232–244.
Kamm JJ, Gillette JR. 1963. Mechanism of stimulation of mammalian nitro reductase by flavins. Life Sci 4:254–260. 10.1016/0024-3205(63)90006-7.
Kamour A, George N, Gwynnette D, 2015. Increasing frequency of severe clinical toxicity after use of 2,4-dinitrophenol in the UK: a report from the National Poisons Information Service. Emerg Med J 32(5):383–386. 10.1136/emermed-2013-203335.24957806
Kato R, Oshima T, Takanaka A. 1969. Studies on the mechanism of nitro reduction by rat liver. Mol Pharmacol 5(5):487–498.4390447
Kaufman DD. 1976. Phenols. In: Kearney PC, Kaufman DD, eds. Herbicides: Chemistry degradation and mode of action. Vol. 2. 2^nd^ ed. New York, NY: Marcel Dekker, Inc., 665–707.
Kavlock RJ, Short RD, Chernoff N. 1987. Further evaluation of an in vivo teratology screen. Teratog Carcinog Mutagen 7(1):7–16. 10.1002/tcm.1770070104.2884745
Kawai A, Goto S, Matsumoto Y, 1987. [Mutagenicity of aliphatic and aromatic nitro compounds. Industrial materials and related compounds]. Sangyo Igaku 29(1):34–54. 10.1539/joh1959.29.34.3613249
Kincannon DF, Lin YS. 1985. Microbial degradation of hazardous wastes by land treatment. Proc Ind Waste Conf 40:607–619.
Kincannon DF, Stover EL, Nichols V, 1983a. Removal mechanisms for toxic priority pollutants. J Water Pollut Contr Fed 55:157–163.
Kincannon DF, Weinert A, Padorr R, 1983b. Predicting treatability of multiple organic priority pollutant waste water from single-pollutant treatability studies. In: Bell JM, ed. Proceedings of the 37th Industrial Waste Conference. Ann Arbor, MI: Ann Arbor Science Publishers, 641–650.
Kinsey VE, Jackson B, Terry TL. 1945. Development of secretory function of ciliary body in the rabbit eye. Arch Ophthal 34:415–417. 10.1001/archopht.1945.00890190419013.
Kleineke J, Söling HD. 1985. Mitochondrial and extramitochondrial Ca2+ pools in the perfused rat liver. Mitochondria are not the origin of calcium mobilized by vasopressin. J Biol Chem 260:1040–1045.3918026
Kleinhofs A, Smith JA. 1976. Effect of excision repair on azide-induced mutagenesis. Mutat Res 41(2–3):233–240. 10.1016/0027-5107(76)90096-8.796715
Klekner V, Kosaric N. 1992. Degradation of phenols by algae. Environ Technol 13(5):493–501. 10.1080/09593339209385176.
Kohping GW, Wiegel J. 1987. Influence of temperature on the anaerobic degradation of substituted phenols in freshwater lake sediments. In: Proceedings of the 87th American Society for Microbiology Annual Meeting, Atlanta, GA, March 1–6. Washington, DC: American Society for Microbiology, 282.
Koizumi M, Yamamoto Y, Ito Y, 2001. Comparative study of toxicity of 4-nitrophenol and 2,4-dinitrophenol in newborn and young rats. J Toxicol Sci 26(5):299–311.11871126
Koizumi M, Yamamoto Y, Ito Y, 2002. Comparative study of the toxicity of 4-nitrophenol and 2,4-dinitrophenol in newborn and young rats. Toxicologist 66(1-S):152–153.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554. 10.1248/jhs.48.545.
Kuck JFR. 1970. Clinical constituents of the lens, metabolism of the lens, cataract formation. In: Graymore CN, ed. Biochemistry of the eye. New York, NY: Academic Press, 183–371.
Kvelland I. 1985. Mutagenicity of five hair dyes in bacteriophage T4D. Hereditas 102(1):151–154. 10.1111/j.1601-5223.1985.tb00475.x.3988538
Lam YY, Ravussin E. 2016. Analysis of energy metabolism in humans: A review of methodologies. Mol Metab 5(11):1057–1071. 10.1016/j.molmet.2016.09.005. http://www.ncbi.nlm.nih.gov/pubmed/27818932.27818932
Lattimore JL. 1934. Dinitrophenol poisoning. J Kans Med Soc 35:388.
Lawford DJ, King E, Harvehoway DG. 1954. On the metabolism of some aromatic nitro-compounds by different species of animal. Part II. The elimination of various nitro-compounds from the blood of different species of animal. J Pharm Pharmacol 6:619–624.13192621
Le P, Wood B, Kumarasinghe SP. 2015. Cutaneous drug toxicity from 2,4-dinitrophenol (DNP): Case report and histological description. Aust J Dermatol 56(4):307–309. 10.1111/ajd.12237.
Lee HC, Law CY, Chen ML, 2014. 2,4-Dinitrophenol: a threat to Chinese body-conscious groups. J Chin Med Assoc 77(8):443–445. 10.1016/j.jcma.2014.05.003.25028287
Lenke H, Pieper DH, Bruhn C, 1992. Degradation of 2,4-dinitrophenol by two Rhodococcus erythropolis strains, HL 24-1 and HL 24-2. Appl Environ Microbiol 58(9):2928–2932. 10.1128/AEM.58.9.2928-2932.1992.1444407
Levesque PC, Atchison WD. 1987. Interactions of mitochondrial inhibitors with methylmercury on spontaneous quantal release of acetylcholine. Toxicol Appl Pharmacol 87(2):315–324. 10.1016/0041-008x(87)90293-6.2435022
Levsen K, Behnert S, Priess B, 1990. Organic compounds in precipitation. Chemosphere 21:1037–1062.
Lichtman SS. 1953. Disease of the liver. In: Diseases of the liver, gallbladder and bile ducts. 3^rd^ ed. Philadelphia, PA: Lea & Febiger, 267–269.
Lipczynska-Kochany E. 1991. Degradation of aqueous nitrophenols and nitrobenzene by means of the Fenton reaction. Chemosphere 22(5–6):529–536. 10.1016/0045-6535(91)90064-k.
Lloyd GK, Ligget MP, Kynoch SR, 1977. Assessment of the acute toxicity and potential irritancy of hair dye constituents. Food Cosmet Toxicol 15(6):607–610. 10.1016/0015-6264(77)90077-3.604238
Lloyd IC, Goss-Sampson M, Jeffrey BG, 1992. Neonatal cataract: aetiology, pathogenesis and management. Eye (Lond) 6 (Pt 2):184–196. 10.1038/eye.1992.37.1624043
Loomis WF, Lipmann F. 1948. Reversible inhibition of the coupling between phosphorylation and oxidation. J Biol Chem 173:807–808.18910739
Looney JM, Hoskins RG. 1934. The effect of dinitrophenol on the metabolism as seen in schizophrenic patients. N Engl J Med 210(23):1206–1213. 10.1056/nejm193406072102303.
Lou P, Hansen BS, Olsen PH, 2007. Mitochondrial uncouplers with an extraordinary dynamic range. Biochem J 407:129–140.17608618
Lu YQ, Jiang JK, Huang WD. 2011. Clinical features and treatment in patients with acute 2,4-dinitrophenol poisoning. J Zhejiang Univ Sci B 12(3):189–192. 10.1631/jzus.B1000265.21370503
Maayan ML. 1968. Effect of dinitrophenol on thyroid responses to thyrotropin. Endocrinology 83(5):938–944. 10.1210/endo-83-5-938.4386777
MacBryde CM, Taussig BL. 1935. Functional changes in liver, heart and muscles and loss of dextrose tolerance due to dinitrophenol. J Am Med Assoc 105:13–17.
Madhosingh C. 1961. The metabolic detoxication of 2,4-dinitrophenol by Fusarium oxysporum. Can J Microbiol 7:553–567. 10.1139/m61-065.13765066
Masserman JH, Goldsmith H. 1934. Dinitrophenol. J Am Med Assoc 102(7):523. 10.1001/jama.1934.02750070021006.
Massini P, Voorn G. 1967. Effect of ferrotoxin and ferrous ion on chloroplast-sensitized photoreduction of dinitrophenol. Photochem Photobiol 6:851–856.6077702
Matzger E. 1934. Can sensitivity to dinitrophenol be determined by skin tests? J Am Med Assoc 103(4):253. 10.1001/jama.1934.72750300001011.
McCarty LS, Mackay D, Smith AD, 1993. Residue-based interpretation of toxicity and bioconcentration QSARs from aquatic bioassays: polar narcotic organics. Ecotoxicol Environ Saf 25(3):253–270. 10.1006/eesa.1993.1024.7691520
McCormick NG, Feeherry FE, Levinson HS. 1976. Microbial transformation of 2,4,6-trinitrotoluene and other nitroaromatic compounds. Appl Environ Microbiol 31(6):949–958. 10.1128/AEM.31.6.949-958.1976.779650
McFee RB, Caraccio TR, McGuigan MA, 2004. Dying to be thin: a dinitrophenol related fatality. Vet Hum Toxicol 46(5):251–254.15487646
McLuckey SA, Glish GL, Carter JA. 1985. The analysis of explosives by tandem mass spectrometry. J Forensic Sci 30(3):11010J. 10.1520/jfs11010j.
Medley DR, Stover EL. 1983. Effects of ozone on the biodegradability of biorefractory pollutants. J Water Pollut Contr Fed 55(5):489–494.
Mill T, Mabey W. 1985. Photochemical transformations. In: Neely W, Glau GE, eds. Environmental exposure from chemicals. Vol. 1. Boca Raton FL: CRC Press, Inc., 207.
Miranda EJ, McIntyre IM, Parker DR, 2006. Two deaths attributed to the use of 2,4-dinitrophenol. J Anal Toxicol 30(3):219–222.16803658
Mitchell AD, Rudd CJ, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at SRI International. Environ Mol Mutagen 12(Suppl 13):37–101. 10.1002/em.2860120504.3416841
Mitra AB, Manna GK. 1971. Effect of some phenolic compounds on chromosomes of bone marrow cells in mice. Indian J Med Res 59:1442–1447.5161571
Miyagawa S. 1977. Differential effects of continuous and short time treatment with 2,4-dinitrophenol on the cell cycle of mouse L cells. Tokushima J Exp Med 24(3–4):147–154.613488
Mudge GH. 1951. Electrolyte and water metabolism of rabbit kidney slices; effect of metabolic inhibitors. Am J Physiol 167(1):206–223. 10.1152/ajplegacy.1951.167.1.206.14885489
Muller-Breitnekamp U, Hockwin O. 1991. Risk factors in cataract development: A review. Dev Ophthamol 21:60–65.
Murphy SD. 1986. Toxic effects of pesticides: Dinitrophenols. In: Klassen CD, Amdur MO, Doull J, eds. Casarett and Doull’s toxicology. New York NY: Macmillan Publishing Co., 555–556.
Muscatello U, Guarriero-Bobyleva V, Buffa P, 1975. Configurational changes in isolated rat liver mitochondria as revealed by negative staining. J Ultrastruct Res 40(3–4):235–260. 10.1016/S0022-5320(72)90098-6.
Mustonen H, Kuosa R, Hoppu K. 2004. Severe poisoning by a fat-burning dietary substance. J Toxicol Clin Toxicol 42(4):546–547.
Nadler JE. 1935. Peripheral neuritis caused by prolonged use of dinitrophenol. J Am Med Assoc 105(1):12. 10.1001/jama.1935.02760270014005.
Nakamura SI, Oda Y, Shimada T, 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: examination with 151 chemicals. Mutat Res 192(4):239–246. 10.1016/0165-7992(87)90063-7.3317033
Namkoong WAN, Loehr RC, Malina JF. 1988. Kinetics of phenolic compounds removal in soil. Haz Waste Haz Mater 5(4):321–328. 10.1089/hwm.1988.5.321.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35.
NCI. 1978. Bioassay of 4-amino-2-nitrophenol for possible carcinogenicity. Bethesda, MD: National Cancer Institute. TR94. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr094.pdf. October 1, 2020.
Neuwoehner J, Schofer A, Erlenkaemper B, 2007. Toxicological characterization of 2,4,6-trinitrotoluene, its transformation products, and two nitramine explosives. Environ Toxicol Chem 26(6):1090–1099. 10.1897/06-471r.1.17571672
NIOSH. 2018. Index of Chemical Abstracts Service Registry Numbers. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 28, 2020.
Nishihata T, Caldwell LJ, Sakai K. 1988a. Inhibitory effect of salicylate on 2,4-dinitrophenol and diethyl maleate in isolated rat intestinal epithelial cells. Biochim Biophys Acta 970(1):7–18. 10.1016/0167-4889(88)90216-9.3130895
Nishihata T, Suzuka T, Yata N, 1988b. Protective effect of salicylate against 2,4-dinitrophenol-induced protein thiol loss in the small intestine of rats. J Pharm Pharmacol 40(7):516–518. 10.1111/j.2042-7158.1988.tb05291.x.2904997
NLM. 2020. PubChem data: 2,4-Dinitrophenol. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/1493. September 30, 2020.
Nojima K, Kawaguchi A, Ohya T, 1983. Studies on photochemical reaction of air pollutants. X. Identification of nitrophenols in suspended particulates. Chem Pharm Bull (Tokyo) 31(3):1047–1051. 10.1248/cpb.31.1047.
NRC. 1982. Drinking water and health. Washington, DC: National Research Council.
NTP. 1988a. Toxicology and carcinogenesis studies of 2-amino-4-nitrophenol in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. TR339. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr339.pdf. October 1, 2020.
NTP. 1988b. Toxicology and carcinogenesis studies of 2-amino-5-nitrophenol in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. TR334. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr334.pdf. October 1, 2020.
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
NWQMC. 2020. Water Quality Portal data: Dinitrophenols. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=2%2C4-Dinitrophenol&mimeType=csv. September 30, 2020.
O’Connor OA, Young LY. 1989. Toxicity and anaerobic biodegradability of substituted phenols under methanogenic conditions. Environ Toxicol Chem 8(10):853–862. 10.1002/etc.5620081003.
O’Connor GA, Lujan JR, Jin Y. 1990. Adsorption, degradation, and plant availability of 2,4-dinitrophenol in sludge-amended calcareous soils. J Environ Qual 19(3):587–593.
Ogino S, Yasukura K. 1957. Biochemical studies on cataract. VI. Production of cataracts in guinea pigs with dinitrophenol. Am J Ophthalmol 43(6):936–946.13424619
Oren A, Gurevich P, Henis Y. 1991. Reduction of nitrosubstituted aromatic compounds by the halophilic anaerobic eubacteria Haloanaerobium praevalens and Sporohalobacter marismortui. Appl Environ Microbiol 57(11):3367–3370. 10.1128/AEM.57.11.3367-3370.1991.1669931
OSHA. 2020a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. September 28, 2020.
OSHA. 2020b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. September 28, 2020.
OSHA. 2020c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. September 28, 2020.
Pace SA, Pace A. 2002. Dinitrophenol oral ingestion resulting in death. J Toxicol Clin Toxicol 40(5):683. 10.1081/CLT-120016859.
Parke DV. 1961. Studies in detoxification: The metabolism of m-dinitro[^14^C]benzene in the rabbit. Biochem J 78(2):262–271. 10.1042/bj0780262.16748875
Parker VH. 1952. Enzymic reduction of 2:4-dinitrophenol by rat-tissue homogenates. Biochem J 51(3):363–370. 10.1042/bj0510363.12977737
Patil SS, Shinde VM. 1988. Simultaneous gas chromatographic determination of nitrobenzene and 2,4-dinitrophenol in nitrobenzene manufacturing plant wastewater. Anal Lett 21(8):1397–1408. 10.1080/00032718808059872.
Patil SS, Shinde VM. 1989. Gas chromatographic studies on the biodegradation of nitrobenzene and 2,4-dinitrophenol in the nitrobenzene plant wastewater. Environ Pollut 57(3):235–250. 10.1016/0269-7491(89)90015-8.15092452
Pearce PJ, Simkins RJ. 1968. Acid strengths of some substituted picric acids. Can J Chem 46:241–248.
Perkins RG. 1919. A study of the munitions intoxications in France. Public Health Rep 34(43):2335–2374.19314692
Perry RJ, Zhang D, Zhang XM, 2015a. Controlled-release mitochondrial protonophore reverses diabetes and steatohepatitis in rats. Science 347(6227):1253–1256. 10.1126/science.aaa0672.25721504
Perry RJ, Zhang D, Zhang X, 2015b. Supplemental material for: Controlled-release mitochondrial protonophore reverses diabetes and steatohepatitis in rats. Science 347(6227) www.sciencemag.org/cgi/content/full/science.aaa0672/DC1.
Phillips L, Singer MA. 2013. Peripheral neuropathy due to dinitrophenol used for weight loss: something old, something new. Neurology 80(8):773–774. 10.1212/WNL.0b013e3182825367.23365059
Pinchot GB. 1967. The mechanism of uncoupling of oxidative phosphorylation by 2,4-dinitrophenol. J Biol Chem 242(20):4577–4583.4964808
Pitter P. 1976. Determination of biological degradability of organic substances. Water Res 10(3):231–235. 10.1016/0043-1354(76)90132-9.
Plumb RH. 1991. The occurrence of appendix IX organic constituents in disposal site ground water. Groundwater Monit Remediat 11(2):157–164. 10.1111/j.1745-6592.1991.tb00378.x.
Politi L, Vignali C, Polettini A. 2007. LC-MS-MS Analysis of 2,4-dinitrophenol and its phase I and II metabolites in a case of fatal poisoning. J Anal Toxicol 31(1):55–61.17389084
Poole FE, Haining RB. 1934. Sudden death from dinitrophenol poisoning: Report of case with autopsy. J Am Med Assoc 102:1141–1147.
Power A, Pearson N, Pham T, 2014. Uncoupling of oxidative phosphorylation and ATP synthase reversal within the hyperthermic heart. Physiol Rep 2(9):1058. 10.14814/phy2.12138.
Prchal JT, Conrad ME, Skalka HW. 1978. Association of presenile cataracts with heterozygosity for galactosaemic states and with riboflavin deficiency. Lancet 1(8054):12–13. 10.1016/s0140-6736(78)90359-8.74495
Probst GS, McMahon RE, Hill LE, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: a comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3(1):11–32. 10.1002/em.2860030103.7021142
Pugsley LI. 1935. The effect of 2:4-dinitrophenol upon calcium, creatine and creatinine excretion in the rat. Biochem J 29(10):2247–2250. 10.1042/bj0292247.16745899
Purvine R. 1936. Fatal poisoning from sodium dinitrophenol. J Am Med Assoc 107(25):2046–2046. 10.1001/jama.1936.92770510002008a.
Quaghebeur D, De Smet B, De Wulf E, 2004. Pesticides in rainwater in Flanders, Belgium: results from the monitoring program 1997–2001. J Environ Monit 6(3):182–190. 10.1039/b312558k.14999316
Rank RT, Waldeck EA. 1936. Cataract; development of following the use of dinitrophenol. Wis Med J August 1936:629–630.
Ravesloot JH, Rombouts E. 2000. 2,4-Dinitrophenol acutely inhibits rabbit atrial Ca^2+^-sensitive Cl^−^ current (I_TO2_). Can J Physiol Pharmacol 78(10):766–773.11077976
Raymond DGM, Alexander M. 1971. Microbial metabolism and cometabolism of nitrophenols. Pestic Biochem Physiol 1(2):123–130. 10.1016/0048-3575(71)90187-8.
RePORTER. 2020. Dinitrophenols. Research Portfolio Online Reporting Tools. National Institutes of Health. http://projectreporter.nih.gov/reporter.cfm. February 21, 2017.
Ribeiro AS, Salerno VP, Sorenson M. 2005. Probing actomyosin interactions with 2,4-dinitrophenol. Biochim Biophys Acta 1748(2):165–173. 10.1016/j.bbapap.2004.12.016.15769593
Richard AM, Hongslo JK, Boone PF, 1991. Structure-activity study of paracetamol analogues: inhibition of replicative DNA synthesis in V79 Chinese hamster cells. Chem Res Toxicol 4(2):151–156. 10.1021/tx00020a005.1782344
Robbins BH. 1944. Dinitrophenol cataract: Production in an experimental animal. J Pharmacol Exp Ther 80:264–268.
Robert TA, Hagardorn AN. 1983. Analysis and kinetics of 2,4-dinitrophenol in tissues by capillary gas chromatography--mass spectrometry. J Chromatogr 276(1):77–84.6672026
Robert TA, Hagardorn AN. 1985. Plasma levels and kinetic disposition of 2,4-dinitrophenol and its metabolites 2-amino-4-nitrophenol and 4-amino-2-nitrophenol in the mouse. J Chromatogr 344:177–186. 10.1016/s0378-4347(00)82018-6.4086539
Robertson JM, Donner AP, Trevithick JR. 1989. Vitamin E intake and risk of cataracts in humans. Ann N Y Acad Sci 570(8054):372–382. 10.1111/j.1749-6632.1989.tb14936.x.2629606
Rodin FH. 1936. Cataracts following the use of dinitrophenol: A summary of thirty-two cases. Cal West Med 44(4):276–279.18743621
RTECS. 1992. Registry of toxic effects of chemical substances. December 1992.
Sax NI, Lewis RJ. 1987. Dinitrophenols. In: Hawley’s condensed chemical dictionary. 11^th^ ed. New York, NY: Van Nostrand Reinhold, 421.
Schlagowski AI, Singh F, Charles AL, 2014. Mitochondrial uncoupling reduces exercise capacity despite several skeletal muscle metabolic adaptations. J Appl Physiol 116(4):364–375. 10.1152/japplphysiol.01177.2013.24336883
Schmidt SK, Gier MJ. 1989. Dynamics of microbial populations in soil: Indigenous microorganisms degrading 2,4-dinitrophenol. Microb Ecol 18(3):285–296. 10.1007/BF02075815.24196208
Schmidt SK, Gier MJ. 1990. Coexisting bacterial populations responsible for multiphasic mineralization kinetics in soil. Appl Environ Microbiol 56(9):2692–2697. 10.1128/AEM.56.9.2692-2697.1990.16348277
Schmidt SK, Smith R, Sheker D, 1992. Interactions of bacteria and microflagellates in sequencing batch reactors exhibiting enhanced mineralization of toxic organic chemicals. Microb Ecol 23(2):127–142. 10.1007/BF00172635.24192859
Schroeder SA, McPhee SJ. 1990. Malignant hyperthermia. In: Current medical diagnosis and treatments. Norwalk, CT: Appleton and Lange, 172.
Schultz B. 1983. Determination of priority pollutant nitrophenols in water by high-performance liquid chromatography. J Chromatogr 269(3):208–212. 10.1016/s0021-9673(01)90806-4.6643596
Schüssler W, Nitschke L. 2001. Nitrophenols in precipitation. Chemosphere 42(3):277–283. 10.1016/s0045-6535(00)00086-2.11100928
Schwarzenbach RP, Stierli R, Folsom BR, 1988. Compound properties relevant for assessing the environmental partitioning of nitrophenols. Environ Sci Technol 22(1):83–92. 10.1021/es00166a009.22195514
Seiler JP. 1981. Testicular DNA synthesis inhibition: An in vivo system for the detection of mutagenic and carcinogenic chemicals. Toxicol Appl Pharmacol 6:233–240. 10.1080/02772248109356950.
Shahin MM. 1985. Mutagenicity evaluation of nitroanilines and nitroaminophenols in Salmonella typhimurium. Int J Cosmet Sci 7(6):277–289. 10.1111/j.1467-2494.1985.tb00422.x. https://www.ncbi.nlm.nih.gov/pubmed/19460039.19460039
Shahin MM, Bugaut A, Kalopissis G. 1982. Mutagenicity of aminonitrophenol compounds in Salmonella typhimurium: a study of structural-activity relationships. Int J Cosmet Sci 4(1):25–35. 10.1111/j.1467-2494.1982.tb00297.x.19469946
Shea PJ, Weber JB, Overcash MR. 1983. Biological activities of 2,4-dinitrophenol in plant-soil systems. Residue Rev 87:11–22. 10.1007/978-1-4612-5479-9_1.
Siegmueller C, Narasimhaiah R. 2010. ‘Fatal 2,4-dinitrophenol poisoning… coming to a hospital near you’. Emerg Med J 27(8):639–640. 10.1136/emj.2009.072892.20511642
Silver S. 1934. A new danger in dinitrophenol therapy. Agranulocytosis with fatal outcome. J Am Med Assoc 103:1058.
Simkins S. 1937a. Dinitrophenol and desiccated thyroid in the treatment of obesity. A comprehensive clinical and laboratory study. J Am Med Assoc 108(25):2110. 10.1001/jama.1937.02780250024006.
Simkins S. 1937b. Dinitrophenol and desiccated thyroid in the treatment of obesity. A comprehensive clinical and laboratory study. Skin reactions. J Am Med Assoc 108(26):2193. 10.1001/jama.1937.02780260021007.
Simpson JR, Evans WC. 1953. The metabolism of nitrophenols by certain bacteria. Biochem J 55(320th Meeting):xxiv.
Sousa D, Carmo H, Roque Bravo R, 2020. Diet aid or aid to die: an update on 2,4-dinitrophenol (2,4-DNP) use as a weight-loss product. Arch Toxicol 94(4):1071–1083. 10.1007/s00204-020-02675-9.32078021
Spencer HC, Rowe VK, 1948. Toxicological studies on laboratory animals of certain alkyldinitrophenols used in agriculture. J Ind Hyg Toxicol 30(1):10–25.18895723
SRI. 1994. 1994 Directory of chemical producers: United States of America. Menlo Park, CA: SRI International.
Stenback F, Garcia H. 1975. Studies on the modifying effect of dimethyl sulfoxide and other chemicals on experimental skin tumor induction. Ann N Y Acad Sci 243:209–227. 10.1111/j.1749-6632.1975.tb25359.x.1055541
Stockton ABCWC. 1934. Clinical circulatory effects of dinitrophenol. J Am Med Assoc 103(12):912–913. 10.1001/jama.1934.02750380032007.
Stone AT, Torrents A, Smolen J, 2002. Adsorption of organic compounds possessing ligand donor groups at the oxide/water interface. Environ Sci Technol 27(5):895–909. 10.1021/es00042a012.
Stryer L. 1988. Oxidative phosphorylation. In: Biochemistry. 3^rd^ ed. New York, NY: W.H. Freeman and Co., 397–426.
Sudhakar B, Siddaramappa R, Sethunathan N. 1976. Metabolism of nitrophenols by bacteria isolated from parathion-amended flooded soil. Antonie Van Leeuwenhoek 42(4):461–470. 10.1007/BF00410177.797317
Suozzi JC, Rancont CM, McFee RB. 2005. DNP 2,4-dinitrophenol: a deadly way to lose weight. JEMS 30(1):82–89.
Suwa Y, Diaz M, Fukui M, 1992. Degradation of 2,4-dinitrophenol by a gram positive bacterium. In: Proceedings of the 92^nd^ American Society for Microbiology General Meeting New Orleans, LA, May 26. Philadelphia, PA: University of Philadelphia, 360.
Swenberg JA, Petzold GL, Harbach PR. 1976. In vitro DNA damage/alkaline elution assay for predicting carcinogenic potential. Biochem Biophys Res Commun 72(2):732–738. 10.1016/s0006-291x(76)80100-3.985507
Tabak HH, Chambers CW, Kabler PW. 1964. Microbial metabolism of aromatic compounds. I. Decomposition of phenolic compounds and aromatic hydrocarbons by phenol-adapted bacteria. J Bacteriol 87(6):910–919. 10.1128/JB.87.4.910-919.1964.14137630
Tabak HH, Quave SA, Mashni CI, 1981a. Biodegradability studies for predicting the environmental fate of organic priority pollutants. In: Test protocols for environmental fate and movement of toxicants: Proceedings of a symposium, Association of Official Analytical Chemists, 94th annual meeting, October 21, 22, 1980, Washington, DC. Arlington, VA: Association of Official Analytical Chemists, 267–328.
Tabak HH, Quave SA, Mashni CI, 1981b. Biodegradability studies for predicting the environmental fate of organic priority pollutants. J Water Pollut Contr Fed 53:1503–1518.
Tainter ML. 1938. Growth, life-span, and food intake of white rats fed dinitrophenol throughout life. J Pharmacol Exp Ther 63:51–57.
Tainter ML, Cutting WC. 1933a. Febrile, respiratory and some other actions of dinitrophenol. J Pharmacol Exp Ther 48:410–429.
Tainter ML, Cutting WC. 1933b. Miscellaneous actions of dinitrophenol Repeated administrations, antidotes, fatal doses, antiseptic tests and actions of some isomers. J Pharmacol Exp Ther 49:187–209.
Tainter ML, Wood DA. 1934. A case of fatal dinitrophenol poisoning. J Am Med Assoc 102:1147. 10.1001/jama.1934.02750140033012.
Tainter ML, Borley WE. 1938. Influence of vitamins and dinitrophenol on the production of experimental cataract. Arch Ophthalmol 20:30–36.
Tainter ML, Cutting WC, Stockton AB. 1934a. Uses of dinitrophenol in nutritional disorders A critical study of clinical results. Am J Public Health 24:1045–1053.
Tainter ML, Cutting WC, Wood DA, 1934b. Di-nitrophenol studies of blood, urine, and tissues of dogs on continued medication and after acute fatal poisoning. Arch Pathol 18:881.
Tainter ML, Stockton AB, Cutting WC. 1935. Dinitrophenol in the treatment of obesity. J Am Med Assoc 105(5):332. 10.1001/jama.1935.02760310006002.
Takahashi N, Nakai T, Satoh Y, 1994. Variation of biodegradability of nitrogenous organic compounds by ozonation. Water Res 28(7):1563–1570. 10.1016/0043-1354(94)90223-2.
Takahashi KL, Hojo H, Aoyama H, 2004. Comparative studies on the spermatotoxic effects of dinoseb and its structurally related chemicals. Reprod Toxicol 18(4):581–588. 10.1016/j.reprotox.2004.02.009.15135852
Takahashi M, Sunaga M, Hirata-Koizumi M, 2009. Reproductive and developmental toxicity screening study of 2,4-dinitrophenol in rats. Environ Toxicol 24(1):74–81. 10.1002/tox.20398.18461559
Tewari A, Ali T, O’Donnell J, 2009. Weight loss and 2,4-dinitrophenol poisoning. Br J Anaesth 102(4):566–567. 10.1093/bja/aep033.19286775
Toyomizu M, Okamoto K, Tanaka M, 1992. Research note: effect of 2,4-dinitrophenol on growth and body composition of broilers. Poult Sci 71(6):1096–1100.1614947
Tratnyek PG, Holgne J. 1991. Oxidation of substituted phenols in the environment: A QSAR analysis of rate constants for reaction with singlet oxygen. Environ Sci Technol 25(9):1596–1604. 10.1021/es00021a011.
Tratnyek PG, Hoigne J, Zeyer J, 1991. QSAR analyses of oxidation and reduction rates of environmental organic pollutants in model ecosystems. Sci Total Environ 109(110):327–341.
Trayhurn P, Van Heyningen R. 1971. Aerobic metabolism in the bovine lens. Exp Eye Res 12(3):315–327. 10.1016/0014-4835(71)90156-4.5130276
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. June 2, 2020.
Trujillo MH, Fragachan GC. 2011. Rhabdomyolysis and acute kidney injury due to severe heat stroke. Case Rep Crit Care 2011:951719. 10.1155/2011/951719.24826326
TSCAPP. 1993. Toxic Substances Control Act, Plant and Production database. Washington, DC: U.S. Environmental Protection Agency.
Tsuda S. 1974. Effects of 2,4-dinitrophenol, sodium arsenate, and oligomycin on mitosis of mouse L cells growing in monolayer culture. Tokushima J Exp Med 21(00):49–59.4413184
USITC. 1970. Synthetic organic chemicals: United States production and sales, 1968. Washington, DC: U.S. International Trade Commission. Publ. 327.
van Veenendaal A, Baten A, Pickkers P. 2011. Surviving a life-threatening 2,4-DNP intoxication: ‘Almost dying to be thin’. Neth J Med 69(3):154.21444944
Vella PA, Munder JA. 1993. Toxic pollutant destruction. ACS Symp Ser 518:85–105. 10.1021/bk-1993-0518.ch005.
Videla L, Israel Y. 1970. Factors that modify the metabolism of ethanol in rat liver and adaptive changes produced by its chronic administration. Biochem J 118(2):275–281. 10.1042/bj1180275.5484675
Wang YT. 1992. Effect of chemical oxidation on anaerobic biodegradation of model phenolic compounds. Water Environ Res 64(3):268–273.
Wegman RCC, Wammes JI. 1983. Determination of nitrophenols in water and sediment samples by high-performance liquid chromatography. Med Fat Landbouwwet Rijksuniv Gent 48:961–969.
Weinbach EC, Garbus J. 1969. Mechanism of action of reagents that uncouple oxidative phosphorylation. Nature 211:1016–1018. 10.1038/2211016a0.
Whalman HF. 1936. Dinitrophenol cataract. Am J Opthalmol 19:885–888.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2015. International chemical safety card: 2,4-dinitrophenol (CAS #: 51-28-5). World Health Organization. ICSC: 0464. http://www.ilo.org/dyn/icsc/showcard.display?p_version=2&p_card_id=0464. June 27, 2018.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wild SR, Jones KC. 1992. Organic chemicals entering agricultural soils in sewage sludges: Screening for their potential to transfer to crop plants and livestock. Sci Total Environ 119(1):85–119. 10.1016/0048-9697(92)90258-T.1631535
Wilkins JN, Mayer SE, Vanderlaan WP. 1974. The effects of hypothyroidism and 2,4-dinitrophenol on growth hormone synthesis. Endocrinology 95(5):1259–1267. 10.1210/endo-95-5-1259.4372035
Williams GM, Laspia MF, Dunkel VC. 1982. Reliability of the hepatocyte primary culture/DNA repair test in testing of coded carcinogens and noncarcinogens. Mutat Res 97(5):359–370. 10.1016/0165-1161(82)90003-6.7144803
WRSIC. 1982. Behavior of organic priority pollutants in the terrestrial system: Di-n-butyl phthalate ester, toluene, and 2,4-dinitrophenol. Washington, DC: Water Resources Scientific Information Center. PB82224544. UNC-WRRI-82–171. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB82224544.xhtml. October 1, 2020.
Wu SN, Li HF, Chiang HT. 2000. Characterization of ATP-sensitive potassium channels functionally expressed in pituitary GH3 cells. J Membr Biol 178(3):205–214.11140276
Wulff LMR, Emge LA, Bravo F. 1935. Some effects of alpha dinitrophenol on pregnancy in the white rat. Proc Soc Exp Biol Med 32:678–680.
Yamamoto H. 1995. A hypothesis for cyanide-induced tonic seizures with supporting evidence. Toxicology 95(1–3):19–26.7825186
Yamasaki K, Ohta R, Okuda H. 2006. OECD validation of the Hershberger assay in Japan: Phase 3. Blind study using coded chemicals. Toxicol Lett 163(2):121–129. 10.1016/j.toxlet.2005.10.001.16289407
Yu-Sun CC, Carter LA, Sandoval L, 1981. Mutagenicity of 4-nitroquinoline 1-oxide and 3 hair dye components in Sordaria brevicollis. Fungal Genet Rep 28(18):1–20.
Zack F, Blaas V, Goos C, 2016. Death within 44 days of 2,4-dinitrophenol intake. Int J Legal Med 130(5):1237–1241. 10.1007/s00414-016-1378-4.27166706
Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9(Suppl9):1–109. 10.1002/em.2860090602.