# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

DNPs are a class of synthetic organic chemicals that exist in six isomeric forms: 2,3-DNP, 2,4-DNP, 2,5-DNP, 2,6-DNP, 3,4-DNP, and 3,5 DNP. Information regarding the chemical identity of DNPs is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of DNPs is located in Table 4-2.

Table 4-1 Chemical Identity of Isomers of Dinitrophenols^a^

Characteristic | Information
Chemical name | 2,3-Dinitrophenol | 2,4-Dinitrophenol | 2,5-Dinitrophenol | 2,6-Dinitrophenol
Synonym(s) | No data | 1-Hydroxy-2,4-dinitrobenzene; α-Dinitrophenol; 2,4-DNP | γ-Dinitrophenol; 2,5-DNP^b^ | β-Dinitrophenol^b^; 2,6-DNP
Registered trade name(s) | No data | Caswell No. 392; Sulfo Black B; Sulfo Black 2b Supra; Nitro Kleenup; others | No data | No data
Chemical formula | C_6_H_4_N_2_O_5_ | C_6_H_4_N_2_O_5_ | C_6_H_4_N_2_O_5_ | C_6_H_4_N_2_O_5_
Chemical structure | Chemical structure | Chemical structure | Chemical structure | Chemical structure
CAS Registry Number^c^ | 66-56-8 | 51-28-5 | 329-71-5 | 573-56-8
Chemical name | 3,4-Dinitrophenol | 3,5-Dinitrophenol | | Dinitrophenol mixture
Synonym(s) | Δ-Dinitrophenol^c^; 4,5-Dinitrophenol^c^ | θ-Dinitrophenol^c^ | | Dinitrophenol solution^c^
Registered trade name(s) | No data | No data | | No data
Chemical formula | C_6_H_4_N_2_O_5_ | C_6_H_4_N_2_O_5_ | | (C_6_H_4_N_2_O_5_)
Chemical structure | Chemical structure | Chemical structure | | Usually a mixture of 2,3-, 2,4-, and 2,6- isomers
CAS Registry Number^c^ | 577-71-9 | 586-11-8 | | 25550-58-7

a All information obtained from CHEMID (1992) and HSDB (1994), except where noted.

b RTECS 1992.

c SANSS 1992.

CAS = Chemical Abstracts Services

Table 4-2 Physical and Chemical Properties of Dinitrophenols

Property | 2,3-Dinitrophenol | 2,4-Dinitrophenol | 2,5-Dinitrophenol | 2,6-Dinitrophenol
Molecular weight | 184.1 | 184.1^a^ | 184.1^a^ | 184.1^a^
Color | Yellow^b^ | Yellow^a^ | Yellow^a^ | Yellow^a^
Physical state | Solid^b^ | Solid^a^ | Solid^a^ | Solid^a^
Melting point | No data | Sublimes^a^ | No data | No data
Boiling point | 144°C^c^ | 112–114°C^a^ | 108°C^a^ | 63–64°C^a^
Density (g/cm^3^) | 1.681^c^ | 1.683^a^ | No data | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water (at 18°C) | No data | 5,600 mg/L^d^ | 385 mg/L at 20°C^e^ | No data
Water (at 35–36°C) | 2,200 mg/L^b^ | 790 mg/L^b^ | 680 mg/L^b^ | 420 mg/L^b^
Organic solvents | No data | Solubility at 15°C (g/100 g solution): 15.55 in ethyl acetate; 35.90 in acetone; 5.39 in chloroform; 20.05 in pyridine; 0.423 in carbon tetrachloride; 6.36 in toluene; soluble in alcohol and benzene^a^ | Slightly soluble in cold alcohol; soluble in hot alcohol, ether, and fixed alkali hydroxides^a^ | Slightly soluble in cold alcohol; freely soluble in chloroform, ether, boiling alcohol, and fixed alkali hydroxides^a^
Partition coefficients:
Log K_ow_ | No data | 1.54^f^ | 1.75^f^ | 1.37^f^
K_oc_ | No data | 1.69^g,e^ | No data | No data
pKa | 4.89^b^ | 4.09^h^ | 5.22^h^ | 3.71^h^
Vapor pressure | No data | 1.49×10^−5^ mmHg^d^ at 18°C | 1.05×10^−3^ mmHg^e^ at 20°C | No data
Henry’s law constant | No data | 2.82×10^−7^ atm-m^3^/mol^e,g^ | 6.61×10^−7^ atm-m^3^/mol^e,g^ | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | 1 ppm=7.65 mg/m^3i^; 1 mg/m3=0.13 ppm | 1 ppm=7.65 mg/m^3i^; 1 mg/m3=0.13 ppm | 1 ppm=7.65 mg/m^3i^; 1 mg/m3=0.13 ppm | 1 ppm=7.65 mg/m^3i^; 1 mg/m^3^=0.13 ppm
Explosive limits | No data | An explosive solid | No data | Moderate explosion hazard exposed to heat^i^
Property | 3,4-Dinitrophenol | 3,5-Dinitrophenol | | Dinitrophenol mixture
Molecular weight | 184.1 | 184.1 | | 184.1
Color | Pale brown^b^ | Colorless^b^ | | Yellow^c^
Physical state | Solid^b^ | Solid^b^ | | Solid^c^
Melting point | 134°C^b^ | 122–123°C^b^ | | No data
Boiling point | No data | No data | | No data
Density (g/cm^3^) | 1.672^b^ | 1.702^b^ | | No data
Odor | No data | No data | | No data
Odor threshold:
Water | No data | No data | | No data
Air | No data | No data | | No data
Solubility:
Water (at 18°C) | No data | No data | | No data
Water (at 35–36°C) | 230 mg/L^b^ | 160 mg/L^b^ | | No data
Organic solvents | No data | No data | | Soluble in alcohol, ether, benzene, and chloroform^c^
Partition coefficients:
Log K_ow_ | No data | 2.36^f^ | | No data
K_oc_ | No data | No data | | No data
pKa | 5.42^h^ | 3.68^b^ | | No data
Vapor pressure | No data | No data | | No data
Henry’s law constant at 25°C | No data | No data | | No data
Autoignition temperature | No data | No data | | No data
Flashpoint | No data | No data | | No data
Flammability limits | No data | No data | | No data
Conversion factors (at 25⁰C, 1 atmosphere) | 1 ppm=7.65 mg/m^3i^; 1 mg/m^3^=0.13 ppm | 1 ppm=7.65 mg/m^3i^; 1 mg/m3=0.13 ppm | | 1 ppm=7.65 mg/m^3i^; 1 mg/m3=0.13 ppm
Explosive limits | No data | No data | | Severe explosion hazard when dry^c,j^

a Budavari et al. 1989.

b Harvey 1959.

c Sax and Lewis 1987.

d Mabey et al. 1981.

e Schwarzenbach et al. 1988.

f Hansch and Leo 1985.

g Estimated value.

h Pearce and Simkins 1987.

i HSDB 1994.

j WHO 2015.