# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR DINITROPHENOLS

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to DNPs.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for DNPs. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of DNPs have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of DNPs are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for DNPs released for public comment in 2019; thus, the literature search was restricted to studies published between April 2016 and June 2020. The following main databases were searched in June 2020:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for DNPs. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to DNPs were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2020 | (((66-56-8[rn] OR “2,3-dinitrophenol”[nm] OR 51-28-5[rn] OR “2,4-Dinitrophenol”[mh] OR 329-71-5[rn] OR “2,5-dinitrophenol”[nm] OR 573-56-8[rn] OR “2,6-dinitrophenol”[nm] OR 577-71-9[rn] OR 586-11-8[rn] OR 25550-58-7[rn] OR “dinitroaminophenol”[nm] OR “3,4-Dinitrophenol”[tw] OR “3,4-DNP”[tw] OR “3,5-Dinitrophenol”[tw] OR “6,5-Dinitrophenol”[tw] OR “Phenol, 3,4-dinitro-”[tw] OR “Phenol, 3,5-dinitro-”[tw]) OR ((“1’alpha-2,4-dinitrophenol”[tw] OR “1-hydroxy-2,4-dinitrobenzene”[tw] OR “2,3-dnp”[tw] OR “2,4-dnp”[tw] OR “2,5-dnp”[tw] OR “2,6-dnp”[tw] OR “aldifen”[tw] OR “camello mosquito coils”[tw] OR “chemox pe”[tw] OR “cobra salts”[tw] OR “dinitroaminophenol”[tw] OR “dinitrophenol”[tw] OR “dinitrophenols”[tw] OR “dinofan”[tw] OR “fenoxyl carbon n”[tw] OR “impregna salts”[tw] OR “maroxol-50”[tw] OR “nitro kleenup”[tw] OR “nitrophen”[tw] OR “nitrophene”[tw] OR “osmoplastic-r”[tw] OR “osmotox-plus”[tw] OR “shirakiku brand mosquito coils”[tw] OR “solfo black 2b supra”[tw] OR “solfo black b”[tw] OR “solfo black bb”[tw] OR “solfo black g”[tw] OR “solfo black sb”[tw] OR “tertrosulphur black pb”[tw] OR “tertrosulphur pbr”[tw] OR “2,3-dinitrophenol”[tw] OR “2,4-dinitrophenol”[tw] OR “2,5-dinitrophenol”[tw] OR “2,6-dinitrophenol”[tw] OR “alpha-dinitrophenol”[tw] OR “beta-dinitrophenol”[tw] OR “gamma-dinitrophenol”[tw] OR “o-dinitrophenol”[tw] OR “p-dinitrophenol”[tw]) NOT medline[sb])) AND (2017/04/01:3000[mhda] OR 2017/04/01:3000[crdt] OR 2017/04/01:3000[edat] OR 2016/04/01:3000[dp])) OR (“1,3-dinitro-4-hydroxybenzene”[tw] OR “aldifren”[tw] OR “dinitrophenate”[tw] OR “ek 102”[tw] OR “phenol, 2,3-dinitro-”[tw] OR “phenol, 2,4-dinitro-”[tw] OR “phenol, 2,5-dinitro-”[tw] OR “phenol, 2,6-dinitro-”[tw] OR “phenol, alpha-dinitro-”[tw] OR “phenol, beta-dinitro-”[tw] OR “phenol, dinitro-”[tw] OR “phenol, gamma-dinitro-”[tw] OR “phenol, α-dinitro-”[tw])
NTRL
06/2020 | “3,4-DNP” OR “Phenol, 3,4-dinitro-” OR “Phenol, 3,5-dinitro-” OR “1 alpha-2,4-dinitrophenol” OR “1-hydroxy-2,4-dinitrobenzene” OR “2,3-dnp” OR “2,4-dnp” OR “2,5-dnp” OR “2,6-dnp” OR “aldifen” OR “camello mosquito coils” OR “chemox pe” OR “cobra salts” OR “dinitroaminophenol” OR “dinitrophenol” OR “dinitrophenols” OR “dinofan” OR “fenoxyl carbon n” OR “impregna salts” OR “maroxol-50” OR “nitro kleenup” OR “nitrophen” OR “nitrophene” OR “osmoplastic-r” OR “osmotox-plus” OR “shirakiku brand mosquito coils” OR “solfo black 2b supra” OR “solfo black b” OR “solfo black bb” OR “solfo black g” OR “solfo black sb” OR “tertrosulphur black pb” OR “tertrosulphur pbr” OR “1,3-dinitro-4-hydroxybenzene” OR “aldifren” OR “dinitrophenate” OR “ek 102” OR “phenol, 2,3-dinitro-” OR “phenol, 2,4-dinitro-” OR “phenol, 2,5-dinitro-” OR “phenol, 2,6-dinitro-” OR “phenol, alpha-dinitro-” OR “phenol, beta-dinitro-” OR “phenol, dinitro-” OR “phenol, gamma-dinitro-” OR “phenol, α-dinitro-”; Date Published 2016 to 2020
Toxcenter
06/2020 | FILE ‘TOXCENTER’ ENTERED AT 11:44:15 ON 05 JUN 2020; CHARGED TO COST=EH038.06.01.LB.02; L1 5846 SEA FILE=TOXCENTER 66-56-8 OR 51-28-5 OR 329-71-5 OR 573-56-8 OR 577-71-9 OR 586-11-8 OR 25550-58-7; L2 5377 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 337 SEA FILE=TOXCENTER L2 AND ED>=20160101; L4 337 SEA FILE=TOXCENTER L2 AND ED>=2016; ACT TOXQUERY/Q; -------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L35 QUE L33 OR L34; -------; L36 172 SEA FILE=TOXCENTER L4 AND L35; L37 47 SEA FILE=TOXCENTER L36 AND MEDLINE/FS; L38 125 SEA FILE=TOXCENTER L36 NOT L37; L39 163 DUP REM L37 L38 (9 DUPLICATES REMOVED) ANSWERS ‘1-163’ FROM FILE TOXCENTER; L*** DEL 47 S L36 AND MEDLINE/FS; L*** DEL 47 S L36 AND MEDLINE/FS; L40 47 SEA FILE=TOXCENTER L39; L*** DEL 125 S L36 NOT L37; L*** DEL 125 S L36 NOT L37; L41 116 SEA FILE=TOXCENTER L39; L42 116 SEA FILE=TOXCENTER (L40 OR L41) NOT MEDLINE/FS D SCAN L42

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
06/2020 | Compounds searched: 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 25550-58-7
NTP
06/2020 | 2016-present:; 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 25550-58-7; “3,4-DNP” “Phenol, 3,4-dinitro-” “Phenol, 3,5-dinitro-” “1 alpha-2,4-dinitrophenol”; “1-hydroxy-2,4-dinitrobenzene” “2,3-dnp” “2,4-dnp” “2,5-dnp”; “2,6-dnp” “aldifen” “camello mosquito coils” “chemox pe”; “cobra salts” “dinitroaminophenol” “dinitrophenol” “dinitrophenols”; “dinofan” “fenoxyl carbon n” “impregna salts” “maroxol-50”; “nitro kleenup” “nitrophen” “nitrophene” “osmoplastic-r”; “osmotox-plus” “shirakiku brand mosquito coils” “solfo black 2b supra” “solfo black b”; “solfo black bb” “solfo black g” “solfo black sb” “tertrosulphur black pb”; “tertrosulphur pbr”; No date limit:; “1,3-dinitro-4-hydroxybenzene” “aldifren” “dinitrophenate” “ek 102”; “phenol, 2,3-dinitro-” “phenol, 2,4-dinitro-” “phenol, 2,5-dinitro-” “phenol, 2,6-dinitro-”; “phenol, alpha-dinitro-” “phenol, beta-dinitro-” “phenol, dinitro-” “phenol, gamma-dinitro-”; “phenol, α-dinitro-”
Regulations.gov
06/2020 | Compounds searched: 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 25550-58-7
NIH RePORTER
09/2020 | Search Criteria: Text Search: “3,4-Dinitrophenol” OR “3,4-DNP” OR “3,5-Dinitrophenol” OR “6,5-Dinitrophenol” OR “Phenol, 3,4-dinitro-” OR “Phenol, 3,5-dinitro-” OR “1’alpha-2,4-dinitrophenol” OR “1-hydroxy-2,4-dinitrobenzene” OR “2,3-dnp” OR “2,4-dnp” OR “2,5-dnp” OR “2,6-dnp” OR “aldifen” OR “camello mosquito coils” OR “chemox pe” OR “cobra salts” OR “dinitroaminophenol” OR “dinitrophenol” OR “dinitrophenols” OR “dinofan” OR “fenoxyl carbon n” OR “impregna salts” OR “maroxol-50” OR “nitro kleenup” OR “nitrophen” OR “nitrophene” OR “osmoplastic-r” OR “osmotox-plus” OR “shirakiku brand mosquito coils” OR “solfo black 2b supra” OR “solfo black b” OR “solfo black bb” OR “solfo black g” OR “solfo black sb” OR “tertrosulphur black pb” OR “tertrosulphur pbr” OR “2,3-dinitrophenol” OR “2,4-dinitrophenol” OR “2,5-dinitrophenol” OR “2,6-dinitrophenol” OR “alpha-dinitrophenol” OR “beta-dinitrophenol” OR “gamma-dinitrophenol” OR “o-dinitrophenol” OR “p-dinitrophenol” OR “1,3-dinitro-4-hydroxybenzene” OR “aldifren” OR “dinitrophenate” OR “ek 102” OR “phenol, 2,3-dinitro-” OR “phenol, 2,4-dinitro-” OR “phenol, 2,5-dinitro-” OR “phenol, 2,6-dinitro-” OR “phenol, alpha-dinitro-” OR “phenol, beta-dinitro-” OR “phenol, dinitro-” OR “phenol, gamma-dinitro-” OR “phenol, α-dinitro-” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

The 2020 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 205
- Number of records identified from other strategies: 28
- Total number of records to undergo literature screening: 233

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on DNPs:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 233
- Number of studies considered relevant and moved to the next step: 31

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 31
- Number of studies cited in the pre-public draft of the toxicological profile: 320
- Total number of studies cited in the profile: 349

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 June 2020 Literature Search Results and Screen for Dinitrophenols

Figure B-1 description