# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrophenols
CAS Numbers: | 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 2550-58-7
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans exposed to 2,4-DNP occupationally (Gisclard and Woodward 1946; Perkins 1919), exposure appeared to involve both the inhalation and dermal routes, and exposure concentrations were not known or inadequately characterized. No studies of health effects in animals exposed to DNP via inhalation were identified in the available literature. Therefore, data are insufficient to derive MRLs for acute-duration inhalation exposure to DNP.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrophenols
CAS Numbers: | 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 2550-58-7
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans exposed to 2,4-DNP occupationally (Gisclard and Woodward 1946; Perkins 1919), exposure appeared to involve both the inhalation and dermal routes, and exposure concentrations were not known or inadequately characterized. No studies of health effects in animals exposed to DNP via inhalation were identified in the available literature. Therefore, data are insufficient to derive MRLs for intermediate-duration inhalation exposure to DNP.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrophenols
CAS Numbers: | 66-56-8; 51-28-5; 329-71-5; 573-56-8; 577-71-9; 586-11-8; 2550-58-7
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans exposed to 2,4-DNP occupationally (Gisclard and Woodward 1946; Perkins 1919), exposure appeared to involve both the inhalation and dermal routes, and exposure concentrations were not known or inadequately characterized. No studies of health effects in animals exposed to DNP via inhalation were identified in the available literature. Therefore, data are insufficient to derive MRLs for chronic-duration inhalation exposure to DNP.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dinitrophenol
CAS Numbers: | 51-28-5
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,4-DNP.

Rationale for Not Deriving an MRL: An MRL derived based on the lowest LOAELs for effects of acute oral exposure to 2,4-DNP would not provide adequate protection, because the POD would fall within an order of magnitude of levels known to cause death in humans. Fatalities have occurred in humans exposed to 2,4-DNP at doses between ~3 and 7 mg/kg/day for 3–14 days (Masserman and Goldsmith 1934; McFee et al. 2004; Poole and Haining 1934). The only effect levels identified at lower doses after acute-duration exposure were LOAELs between 0.9 and 2 mg/kg/day for dermal lesions (Anderson et al. 1933; Hitch and Schwartz 1936; Lee et al. 2014; Nadler 1935), decreased body weight (Tainter et al. 1935), cataracts (Hitch and Schwartz 1936), and polyneuritis (Hitch and Schwartz 1936) in human case reports or clinical studies from the 1930s. Use of any of these LOAELs as the POD for acute-duration oral MRL derivation may not provide adequate protection against the lethal effects of 2,4-DNP, because the dose estimates for human case reports are in some cases uncertain (when body weight information is not reported) and the difference between death and less severe effects is extremely small. Furthermore, variability in susceptibility to pyrexia with changes in ambient temperature have been reported in animals (Harvey 1959), raising the possibility that lower doses may be fatal in humans exposed to 2,4-DNP at higher ambient temperatures. No acute-duration studies of 2,4-DNP in animals used dose levels below those associated with lethality in humans, so animal data cannot be used to derive an acute MRL. Therefore, data are insufficient to derive an acute MRL for exposure to 2,4-DNP.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dinitrophenol
CAS Numbers: | 51-28-5
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.00007 mg/kg/day
Critical Effect: | Decreased body weight
Reference: | Caldeira da Silva et al. 2008
Point of Departure: | LOAEL of 0.07 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 85
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.00007 mg/kg/day was derived for 2,4-DNP based on decreased body weight in mice exposed to 0.07 mg/kg/day 2,4-DNP in drinking water for 50 weeks (Caldeira da Silva et al. 2008). The MRL is based on a LOAEL of 0.07 mg/kg/day and a total uncertainty factor of 1,000 (10 for interspecies extrapolation, 10 for human variability, and 10 for use of a LOAEL).

Selection of the Critical Effect: Human fatalities have been reported after acute- and intermediate-duration oral exposures to 2,4-DNP doses as low as 1–5 mg/kg/day (Dameshek and Gargill 1934; Goldman and Haber 1936; Masserman and Goldsmith 1934; Silver 1934; Zack et al. 2016). The only effects reported at lower doses in humans or animals were decreased body weight (at least 10% lower than controls after 20 weeks of exposure) and decreased serum glucose, triglycerides, and insulin (after 12 weeks of exposure) in a chronic mouse study in which 2,4-DNP was administered at an average dose of 0.07 mg/kg/day in drinking water (Caldeira da Silva et al. 2008). The mice were maintained at a lower ambient temperature (22°C) than normal to enable heat to dissipate; thus, it is not possible to assess whether hyperthermia might also occur at this exposure level. A clinical study in humans provides limited support for the effects of 2,4-DNP on serum glucose and insulin, as decreased glucose tolerance was seen after acute and intermediate exposures to 4 mg/kg/day 2,4-DNP (MacBryde and Taussig 1935).

In contrast, there are abundant data indicating that oral 2,4-DNP exposure results in decreased body weight or decreased body weight gain in humans and animals. Decreases in body weight have been reported in humans exposed to acute- (Anderson et al. 1933; Bortz 1934; Cutting and Tainter 1933; Tainter et al. 1935), intermediate- (Beinhauer 1934; Boardman 1935; Cutting et al. 1933, 1934; Horner et al. 1935; Looney and Hoskins 1934; Masserman and Goldsmith 1934; Nadler 1935; Simkins 1937a, 1937b; Tainter et al. 1935; Whalman 1936), and chronic-duration (Horner et al. 1935) doses of 1–4 mg/kg/day. Likewise, body weight decrements have been reported in intermediate- (Bakke and Lawrence 1965; Goldgof et al. 2014; Koizumi et al. 2001, 2002; Pugsley 1935; Spencer et al. 1948; Tainter and Borley 1938; Takahashi et al. 2009) and chronic-duration (Tainter 1938) studies in rats and mice, albeit at much higher doses (≥20 mg/kg/day). Furthermore, the mechanism for 2,4-DNP-induced decreases in body weight is well established: 2,4-DNP uncouples oxidative phosphorylation, leading to an increase in basal metabolic rate and an increase in carbohydrate consumption as the body endeavors to produce ATP needed for cell functions. In summary, decreased body weight occurs in both humans and animals exposed to 2,4-DNP by a well-studied mode of action, and was selected as the critical effect for MRL derivation.

Selection of the Principal Study: The Caldeira da Silva et al. (2008) study provided the lowest adverse effect level.

Summary of the Principal Study:

Caldeira da Silva CC, Cerqueira FM, Barbosa LF, 2008. Mild mitochondrial uncoupling in mice affects energy metabolism, redox balance and longevity. Aging Cell 7(4):552–560.18505478

Six groups (three pairs of control and exposed groups) of 30 female Swiss mice were exposed to DNP in drinking water at a concentration of 0 or 1 mg/L beginning at 18 weeks of age (Caldeira da Silva et al. 2008). The animals were housed at 22°C to allow heat due to uncoupling to dissipate and to prevent hyperthermia. Food and water intake and body weight were recorded weekly. The authors reported that the animals received doses between 0.03 and 0.105 mg/kg/day (midpoint of the dose range is 0.07 mg/kg/day) based on body weight and water intake. At 22 and 32 weeks of age (after 4 and 14 weeks of exposure), one exposed and one control group each were sacrificed for evaluation of oxygen consumption and oxidative stress in the heart, brain, and liver (oxidative stress was measured as peroxide release, protein carbonyl signal, and oxidative DNA adducts). In the groups sacrificed at 32 weeks of age (14 weeks of exposure), blood was collected for analysis of triglycerides, glucose, and insulin. The third sets of exposed and control groups were observed until natural death; the only endpoints assessed in these animals were food and water intake, body weight, body temperature, and survival.

Serum levels of glucose, triglycerides, and insulin were significantly lower than controls after 14 weeks of DNP treatment. Oxygen consumption was significantly increased in the brain and liver of exposed mice, but not in the heart. In all three organs, oxidative stress was reduced by exposure to DNP. In the groups exposed for their natural lifespans, food and water intake, and body temperature at 75 weeks of age did not differ from controls. Exposed mice exhibited significantly reduced body weight (~8–13% less than controls based on digitization of data shown graphically; see Table A-1) after the first 20 weeks of exposure; the decrease persisted throughout the study. The last body weight measurement reported in the study was ~week 68, reflecting at least 50 weeks of exposure. Mean lifespan was significantly higher in exposed mice than in controls.

Table A-1 Body Weight Changes Over Time in Mice Exposed to 2,4-Dinitrophenol in Drinking Water from 18 Weeks of Age until Natural Death^a^

Mouse age (weeks) | Exposure duration (weeks) | Approximate body weight (g) | | Approximate percent change from control
Mouse age (weeks) | Exposure duration (weeks) | Control | Exposed | Approximate percent change from control
18 | Pretreatment | 40 | 39 | Not applicable
28 | 10 | 48 | 45 | 6%
38 | 20 | 51 | 47^b^ | 8%
48 | 30 | 55 | 50^b^ | 9%
58 | 40 | 56 | 51^b^ | 9%
68 | 50 | 55 | 48^b^ | 13%^c^

a Mice were exposed for ~140 weeks, but the only body weight data presented were measurements through the first 50 weeks of exposure.

b Significantly different from control mean, p<0.05.

c Exceeds ATSDR benchmark for adverse change in body weight (10% change from control mean).

Source: Caldeira da Silva et al. (2008). Data digitized from Figure 1 using Grab It!^TM^.

Selection of the Point of Departure for the MRL: The LOAEL of 0.07 mg/kg/day (midpoint of the dose range reported by the authors) for decreased body weight was selected as the POD for deriving an MRL for intermediate-duration oral exposure to DNP. Benchmark dose modeling was not considered for this dataset, as only one drinking water concentration was used in the critical study.

Calculations: None.

Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL of 0.07 mg/kg/day was divided by a total uncertainty factor of 1,000:

- 10 for interspecies extrapolation
- 10 for use of a LOAEL
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: See Selection of the Critical Effect above.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dinitrophenol
CAS Numbers: | 51-28-5
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,4-DNP.

Rationale for Not Deriving an MRL: An MRL derived based on the lowest LOAELs for effects of chronic oral exposure to 2,4-DNP would not provide adequate protection, because the POD would be at or above dose levels known to cause death in humans. However, the intermediate-duration oral MRL is believed to be protective for chronic exposures.

Only two chronic-duration studies of 2,4-DNP (Horner et al. 1935; Tainter 1938) provided enough information to identify effect levels, and the effect levels were at or above doses associated with human fatalities. The NOAELs and LOAELs in the Horner et al. (1935) human study and Tainter (1938) were 2 and 30 mg/kg/day, respectively, and human fatalities have been reported after acute- or intermediate-duration exposures of 1–5 mg/kg/day (Dameshek and Gargill 1934; Goldman and Haber 1936; Masserman and Goldsmith 1934; Silver 1934; Zack et al. 2016).

Caldeira da Silva et al. (2008) included an experiment with chronic-duration exposure (mice were exposed from 18 weeks of age until their natural deaths), but the only endpoints evaluated in the groups exposed until natural death were food and water intake, body weight, body temperature, and survival. Furthermore, the authors reported data on food and water intake and body temperature only at 75 weeks of age (57 weeks of exposure), and on body weights only through 68 weeks of age (50 weeks of exposure). The intermediate-duration MRL is based on the LOAEL for decreased body weight in mice in the study by Caldeira da Silva et al. (2008). In this study, the mice exhibited body weight decrements of 8–13% less than controls between 20 and 50 weeks of exposure. The body weight data, reported graphically, showed a persistent or slightly expanding decrement from control weights over the exposure period.

The intermediate-duration MRL is believed to be protective for chronic exposures, for several reasons. The exposure duration in the critical experiment was just short of 1 year (50 weeks, or 350 days), and thus approximated a chronic duration (≥365 days). In addition, as noted above, the body weight data showed a continued trend in reduced weight throughout the experiment that is likely to have persisted with longer exposure. Furthermore, available chronic-duration studies in humans (Horner et al. 1935) and rodents (Tainter 1938) indicated that weight loss is a common and sensitive effect of chronic exposure to 2,4-DNP. Finally, the mechanism for the weight loss (uncoupling of oxidative phosphorylation and increased basal metabolic rate) is very well characterized, and is expected to be operant at all exposure durations.

Agency Contacts (Chemical Managers): Jennifer Przybyla