# CHAPTER 8 REFERENCES

*Cited in text

Abrams K, Hogan DJ, Maibach HI. 1991. Pesticide-related dermatoses in agricultural workers. Occup Med State Art Rev 6:463–492.
*ACGIH. 1986. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental and Industrial Hygienists. Cincinnati, OH, 20.
*ACGIH. 2016. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adler B, Braun R, Schoeneich J, . 1976. Repair-defective mutants of Proteus mirabilis as a prescreening system for the detection of potential carcinogens. Biologisches Zentralblatt 95:463–469.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Alber M, Boehm HB, Brodesser J, . 1989. Determination of nitrophenols in rain and snow. Fresenius J Anal Chem 334:540–545.
*Ambrose AM. 1942. Some toxicological and pharmacological studies on 3,5-dinitro-o-cresol. J Pharmacol Exp Ther 76:245–251.
*Amman HU. 1985. Parameters governing the leaching of chemicals in the soil. Les Colloquilles de 1’INRA 31:105–116.
*Andersen KJ, Leighty EG, Takahashi MT. 1972. Evaluation of herbicides for possible mutagenic properties. J Agric Food Chem 20(3):649–656.4561194
*Anonymous. 1934. Medicine and the law. Death after slimming treatment. Dekrysil treatment: The Paddington inquest. Lancet 1:489–490, 652.
*Anonymous. 1938. Weight controls. Cataracts develop following use of anti-fat nostrum. JAMA 111(2):188–189.
*Anonymous. 1951. Toxic chemicals in agriculture. Br Med J 1:628–630.20788033
*Arustamyan, AN. 1972. [Toxicity of dinitro-o-cresol (dinoc) for rabbits.] TR Inst Vet Sanit 45:166–169. (Russian)
Ashby J. 1986. The prospects for a simplified and internationally harmonized approach to the detection of possible human carcinogens and mutagens. Mutagenesis 1:3–16.3325732
*Atkinson R. 1988. Estimation of gas-phase hydroxyl radical rate constants for organic chemicals. Environ Toxicol Chem 7:435–442.
*Atkinson R, Aschmann SM, Arey J. 1992. Reactions of OH and NO_3_ radicals with phenol, cresols, and 2-nitrophenyl at 296 Π K. Environ Sci Technol 26:1397–1403.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. 4,6-Dinitro-o-cresol. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Bailey GW, White JL. 1965. Herbicides: A compilation of their physical, chemical and biological properties. Residue Rev 10:97–122.4865270
Baran RL. 1974. Nail damage caused by weed killers and insecticides. Arch Dermatol 110:467.4451403
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnes JM. 1975. The widespread use of pesticides. J Clin Pathol Suppl (Assoc Clin Pathol) 9:115–118.
Barthel E. 1981. Increased risk of lung cancer in pesticide exposed male agricultural workers. In: American Society for Pharmacology and Experimental Therapeutics Symposium on Molecular Mechanism(s) of Toxicity of Chlordecone (Kepone), Rochester, MN, August 20, 1980. J Toxicol Environ Health 8:1027–1040.7338938
*Batchelor GS, Walker KC, Elliott JW. 1956. Dinitroorthocresol exposure from apple-thinning sprays. AMA Arch Indus Health 13:593–596.
*Ben-Dyke R, Sanderson DM, Noakes DN. 1970. Acute toxicity on pesticides, 1970. World Rev Pest Control 9:119–127.
*Benadikova H, Kalvoda R. 1984. Adsorptive stripping voltammetry of some triazine- and nitro-group-containing pesticides. Anal Lett 17:1519–1531.
Bidstrup PL. 1952. Clinical aspects of poisoning by dinitro-ortho-cresol. Proc R Sot Med 45:574–575.
*Bidstrup PL, Bonnell JAL, Harvey DG. 1952. Prevention of acute dinitro-ortho-cresol (DNOC) poisoning. Lancet 1:794–795.
*Bidstrup PL, Payne JH. 1951. Poisoning by dinitro-ortho-cresol report of eight fatal cases occurring in Great Britain. Br Med J 2:16–19.14839312
Blondin GA, Knobeloch LM, Read HW, . 1987. Mammalian mitochondria as in vitro monitors of water quality. Bull Environ Contam Toxicol 38:467–474.3814871
*Bollen WB. 1961. Interactions between pesticides and soil microorganisms. Annu Rev Microbial 15:69–92.
Braun R, Steinborn S. 1990. Induction of UDS in primary mouse hepatocyte cultures by some frameshift mutagens [abstract]. Mutat Res 234:430.
*Braunbeck T, Volkl A. 1991. Induction of biotransformation in the liver of Eel (Anguilla anguilla L.) by sublethal exposure to dinitro-o-cresol: An ultrastructural and biochemical study. Ecotoxicol Environ Safety 21(2):109–127.2065626
*Britt BA. 1979. Etiology and pathophysiology of malignant hyperthermia. Fed Proc 38:44–48.759238
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous material exposure. St. Louis, MO: CV Mosby Co., 159–160.
Bruinsma J. 1960. The action of 4,6-dinitro-o-cresol (DNOC) in soil: I. The emergence from cress seed in DNOC-treated soil mixtures. Plant and Soil XII(3):39–47.
*Buchholz KD, Pawliszyn J. 1993. Determination of phenols by solid-phase microextraction and gas chromatographic analysis. Environ Sci Technol 27(13):2844–2848.
*Buchinskii VN. 1974. [Fatal poisoning by dinitrocresol.] Sudebne Meditsinskaya Ekspertiza 1752–53. (Russian)
*Budzinski H, Hermange Y, Pierard C, . 1992. Structural characterization of environmentally important compounds by gas chromatography/Fourier transform infrared spectroscopy (GC/FTIR) and gas chromatography/mass spectrometry (GUMS). Analysis 20(3):155–163.
*Burkatskaya EN. 1965a. [Maximum permissible concentration of dinitro-o-cresols in air.]. Gig Sanit 30:34–37. (Russian)
*Burkatskaya EN. 1965b. [The toxicity of dinitro-orthocresols for warm-blooded animals and problems of industrial hygiene in its applications.] Gig Tr Prof Zabol 9(4):56–57. (Russian)
*Buschke W. 1947. Acute reversible cataract in chicken due to various nitrocompounds. Am J Ophthalmol 30:1356–1368.20269945
*Buzzo A, Guatelli MA. 1949. [Contribution to the toxicologic study of dinitro-o-cresol DNOC.] Rev Assoc Bioquim Argent 14:24–40 (Spanish)
*Capel PD, Giger W, Reichert P, . 1988. Accidental input of pesticides into Rhine River. Environ Sci Technol 22(19):992–997.22148648
*Castilho RF, Vicente JA, Kowaltowski AJ, . 1997. 4,6-Dinitro-o-cresol uncouples oxidative phosphorylation and induces membrane permeability transition in rat liver mitochondria. Int J Biochem Cell Biol 29(7):1005–1011.9375380
CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
CELDs. 1992. Computer Aided Environmental Legislative Data System. 1992.
CELDs. 1994. Computer Aided Environmental Legislative Data System. 1994.
*Cessna AJ, Grover R. 1978. Spectrophotometric determination of dissociation constants of selected acidic herbicides. J Agric Food Chem 26:289–292.
*Chambers CW, Kabler PW. 1964. Biodegradability of phenols as related to chemical structure. In: Developments in industrial microbiology. Vol. 5. New York: Plenum Press, 85–93.
*Chambers CW, Tabak HH, Kabler PW. 1963. Degradation of aromatic compounds by phenol-adapted bacteria. J Water Pollut Control Fed 35:1517–1528.
*Chao YC, Whang CW. 1994. Capillary zone electrophoresis of eleven priority phenols with indirect fluorescence detection. J Chromatogr 663:229–237.
*ChemID. 1993. On-line database. January 6, 1993.
*Clarke ML, Harvey DG, Humphreys DJ. 1981. Veterinary toxicology. 2nd ed. London, England: Balliere Tindall, 134–136.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coats JR. 1987. Toxicology of pesticide residues in foods. In: Hathcock JN, ed. Nutrition: Basic and applied science: A series of monographs. Nutritional toxicology. Vol. II. London, England: Academic Press, 249–280.
*Cohen DB. 1986. Ground water contamination by toxic substances. A California assessment. ACS Symposium Series 315, 499–529.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
*Den Tonkelaar EM, Van Leeuwen FXR, Kuiper C. 1983. Semichronic toxicity testing of DNOC in the rat. Meded Fat Landbouwwet Rijksuniv Gent 48:1015–1022.
*Devault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
*Di Corcia A, Marchetti M. 1992. Method development for monitoring pesticides in environmental waters: Liquid-solid extraction followed by liquid chromatography. Environ Sci Technol 26(1):66–74.
*Dobbs RA, Jelus M, Cheng KY. 1987. Partitioning of toxic organic compounds on municipal wastewater treatment plant solids. In: Scholze RJ Jr, ed. Proceedings of the Innovative Biologic Treatment of Toxic Wastewaters International Conference, 584–600.
*Dobbs RA, Wang L, Govind R. 1989. Sorption of toxic organic compounds on wastewater solids: Correlation with fundamental properties. Environ Sci Technol 23:1092–1097.
*Dodds EC, Robertson JD. 1933. The clinical applications of dinitro-o-cresol. Lancet 2:1137–1139.
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for chemicals of concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
*Dow Chemical Co. 1940. Initial submission: Toxicity and health hazards of 2,4-dinitrophenol, dinitro-ortho-cresol, and dinitro-ortho-cyclohexyl phenol (final report) with letter dated 031892 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0536148.
*Dow Chemical Co. 1950. Initial Submission: The comparative acute oral toxicity of several dinitrophenols used in agriculture (final report) with cover letter dated 031892 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0536145.
Dunachie JF, Fletcher WW. 1969. Investigation of the toxicity of insecticides to birds’ eggs using the egg-injection technique. Ann Appl Biol 64:409–423.
*Durham WF, Wolfe HR. 1962. Measurement of the exposure of workers to pesticides. Bull WHO 26:75–91.13888659
Edson EF. 1954. Estimation of dinitro-ortho-cresol in blood. Lancet. 1:981–982.
Edson EF. 1969. Chemical hazards in agriculture. Ann Occup Hyg 12:99–108.5767608
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York: Elsevier, 1096–1097.
*EPA. 1973a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1973b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.3.
*EPA. 1976a. Frequency of organic compounds identified in water. Washington, DC: U.S. Environmental Protection Agency, 102. EPA600476062.
*EPA. 1976b. Investigation of selected potential environmental contaminants: Nitroaromatics. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560276010.
*EPA. 1978. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.20.
*EPA. 1979. Water-related environmental fate of 129 priority pollutants. Vol. II: Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency. EPA440479029B.
*EPA. 1980a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1980c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1981. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1982a. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600482057.
*EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423, Appendix A.
*EPA. 1983a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D.
*EPA. 1983b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.42.
*EPA. 1983c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
*EPA. 1984a. Method 604-phenols. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1984b. Method 625-Base/Neutrals and Acids. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1984c. Method 1625 Revision B-Semivolatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1984d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix IX.
*EPA. 1986a. Phenols-method 8040. In: Test methods for evaluating solid wastes SW-846. 3rd ed., Volume 1B, Laboratory Manual. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique-method 8270. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume 1B. Laboratory manual. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. Test method for evaluating solid wastes, SW846. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1986d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
*EPA. 1987a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.91.
*EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.101.
*EPA. 1987c. U.S. Environmental Protection Agency. Emergency planning and notification. 40 CFR 355, Appendix A.
*EPA. 1988a. Health and environmental effects profile for dinitrocresols. Cincinnati, OH: U.S. Environmental Protection Agency. NTIS PB88220769.
*EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988c. U.S. Environmental Protection Agency. Treatment standards expressed as waste concentrations. 40 CFR 268.43.
*EPA. 1989a. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA/600/8-90/066F.
*EPA. 1989b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
EPA. 1991a. Reportable quantity for chronic systemic toxicity and potential carcinogenicity of 4,6-dinitro-o-cresol. ECAO-CIN-R117A. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office.
*EPA. 1991b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, Appendix II.
EPA. 1992a. Effluent limitations representing degree of effluent reduction attainable by the application of the best practical technology economically available (BAT). Code of Federal Regulations. 40 CFR 414.
*EPA. 1992b. U.S. Environmental Protection Agency. Hazardous constituents. 40 CFR 261, Appendix VIII, 90–97.
*EPA. 1992c. U.S. Environmental Protection Agency. Designation, reportable quantities, and notification. 40 CFR 302.4.
*EPA. 1993a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.111.
*EPA. 1993b. Status of Pesticides in Reregistration and Special Review. EPA738R93009. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. June 15, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) Values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*ERM Program Management Co. 1992. Initial submission: Results concerning the comparative study of the acute toxicity of several nitrocresols in rabbits. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000847.
Ernst W. 1967. Der Stoffwechsel von Pesticiden in Stugetieren. Residue Rev l8:131–157.
*Farm Chemicals Handbook. 1993. Farm Chemicals Handbook 1993. Willoughby, OH: Meister Publishing Company.
*Farrington DS, Martindale RW, Woollam CJ. 1982. Determination of the active ingredient content of technical and formulated dinobuton, dinoseb, dinoterb and DNOC by high-performance liquid chromatography, spectrophotometry, and gas-liquid chromatography. Analyst 107:71–75.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
FEDRIP. 1994. Federal Research in Progress. August 1994.
Foster TS. 1974. Physiological and biological effects of pesticide residues in poultry. Residue Rev 51:69–121.
*Frissel MJ, Bolt GH. 1962. Interaction between certain ionizable organic compounds (herbicides) and clay minerals. Soil Science 94:284–291.
Froslie A. 1971a. Methaemoglobin formation in vitro by 6-amino metabolites of DNOC and DNBP. Acta Pharmacol Toxicol (Copenh) 29:490–498.5171122
Froslie A. 1971b. The difference in methaemoglobin formation by 6-amino metabolites of DNOC and DNBP in ruminant and nonruminant animals with special reference to sheep and swine. Acta Pharmacol Toxicol (Copenh) 0:238–247.
*Froslie A. 1973. Methaemoglobin formation by diamino metabolites of DNOC and DNBP. Acta Pharmacol Toxicol (Copenh) 32:257–265.4801726
Froslie A. 1974. Effects following intraruminal administration of DNOC [2-methyl-4,6-dinitrophenol] and DNBP [2-(l-methyl-n-propyl)-4,6-dinitrophenol] to sheep. Acta Vet Stand Suppl 49:61.
Froslie A, Karlog 0. 1970. Ruminal metabolism of DNOC and DNBP. Acta Vet Stand 11:114–132.
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal State Toxicology and Regulator Alliance Committee. February 1990.
Galea V, Ariesan M, Preda N. 1965. Toxicity of DNOC in tadpoles and in white rats. Farmacia (Bucharest) 13:485–489.
*Golovleva LA, Aliyeva RM, Naumova RP, . 1992. Microbial bioconversion of pollutants. Rev Environ Contam Toxicol 124:41–78.1732995
*Gordon MB, Wallfield MJ. 1935. Toxic reaction of alpha-dinitro-ortho-cresol. Ann Intern Med 9:198–200.
*Goring CAI, Laskowski DA, Hamaker JW, . 1975. Principles of pesticides degradation in soil. In: Haque R, Freed VH, eds. Environmental dynamics of pesticides. New York, NY: Plenum Press, 135–172.
*Great Lakes Water Quality Board. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. 1: Summary. Report to the Great Lakes Water Quality Board, Windsor, Ontario, Canada.
Green S, Auletta A, Fabricant J, . 1985. Current status of bioassays in genetic toxicology 2 the dominant lethal assay. A report of the U.S. Environmental Protection Agency Gene-Tox Program. Mutat Res 154:49–67.3889623
*Grilli S, Ancora G, Rani P, . 1991. In vivo unwinding fluorimetric assay as evidence of the damage induced by fenarimol and DNOC in rat liver DNA. J Toxicol Environ Health 34:485–494.1960763
*Grosjean D. 1984. Atmospheric reactions of ortho cresol: Gas phase and aerosol products. Atmos Environ 18(8):1641–1652.
*Grosjean D. 1985. Atmospheric reactions of styrene and peroxybenzoyl nitrate. Sci Total Environ 46:41–59.
*Grosjean D. 1991. Atmospheric fate of toxic aromatic-compounds. Sci Total Environ 100:367–414.
*Gundersen K, Jensen HL. 1956. A soil bacterium decomposing organic nitro compounds. Acta Agriculturae Scandinavica 6:100–l14.
*Gurka DF, Pyle SM, Farnham I, . 1991. Application of hyphenated Fourier Transform-infrared techniques to environmental analysis. J Chromatogr Sci 29(8):339–344.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose, 2nd ed. Philadelphia: WB Saunders, 1291–1292.
Hagan DF, Markell CG, Wisted EE. 1993. Solid-phase extraction of phenols using membranes loaded with modified polymeric resins. J Chromatogr 641:57–61.
*Halfon E, Bruggemann R. 1989. Environmental hazard of eight chemicals present in the Rhine River. Water Sci Technol 21:815–820.
*Hall LW Jr, Hall WS, Bushong SJ, . 1987. In situ striped bass (Morone saxatilis) contaminant and water quality studies in the Potomac River. Aquatic Toxicol 10:73–99.
*Hamaker JW, Kerlinger HO. 1969. Vapor pressures of pesticides. Adv Chem Series 86, 39–54.
*Hamdi YA, Tewfik MS. 1970. Degradation of 3,5-dinitro-o-cresol by Rhizobium and Azotobacter species. Soil Biol Biochem 2:163–166.
*Harvey DG. 1953. The toxicity of the dinitro-cresols: Part II: The formation and toxic properties of some nitro compounds derived from meta- and para-cresols. J Pharm Pharmacol 5:497–510.13070179
*Harvey DG. 1959. On the metabolism of some aromatic nitro compounds by different species of animal. Part III. The toxicity of the dinitrophenols, with a note on the effects of high environmental temperatures. J Pharm Pharmacol 11:462–474.14400214
*Harvey DG, Bidstrup PL, Bonnell JAL. 1951. Poisoning by dinitro-ortho-cresol. Some observations on the effects of dinitro-ortho-cresol administered by mouth to human volunteers. Br Med J 2:13–16.14839311
*Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
*Hawley GG. 1981. The Condensed Chemical Dictionary. 10th ed. New York: Van Nostrand Reinhold Co., 374.
HAZDAT. 1992. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. October 30, 1992.
*Herterich R. 1991. Gas chromatographic determination of nitrophenols in atmospheric liquid water and airborne particulates. J Chromatogr 549:313–324.
*Hake RQ, Giesy JP, Zabik M, . 1993. Toxicity of sediments and sediment pore waters from the Grand Calumet River-Indian Harbor, Indiana Area of Concern. Ecotox Environ Safety 26:86–112.
Holden HE. 1982. Comparison of somatic and germ cell models for cytogenetic screening. J Appl Toxicol 2:196–200.7185901
*Holden PW. 1986. Pesticides and groundwater quality. Washington, DC: National Academy Press.
*Hopper ML, McMahon B, Griffitt KR, . 1992. Analysis of fatty and nonfat foods for chlorophenoxy alkyl acids and pentachlorophenol. J AOAC 75:707–713.
*Homer WD. 1941. A study of dinitrophenol and its relation to cataract formation. Trans Am Ophthalmol Soc 39:405–437.16693262
Homer WD. 1942. Dinitrophenol and its relation to formation of cataracts. Arch Ophthalmol 27:1097–1121.
*Hrelia P, Morotti M, Scotti M, . 1990. Genotoxic risk associated with pesticides evidence on short-term tests. V. In: Inter-regional meeting of the Emilia-Romagna, Friuli-Venezia Giulia, Marche, Trentino-Alto Adige, Venetoá Group of the Italian Pharmacological Society, Trieste, Italy, June 1, 1990. Pharmacol Res Commun 22(Suppl 3):93–94.
*Hrelia P, Vigagni F, Maffei F, . 1994. Genetic safety evaluation of pesticides in different short-term tests. Mutat Res 321(4):219–228.7515160
HSDB. 1992. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD.
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD.
*Hunter D. 1950. Dinitro-ortho-cresol. In: Devices for the protection of the worker. Br Med J 1509–512.
*Hurle K, Rademacher B. 1970. [Untersuchungen ueber den Einfluss landjaehrig weiderholter Anwendung von DNOC und 2,4-D auf ihren Abbau im Boden.] Weed Research 10:159–164. (German)
*IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–118. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. June 16, 2017.
*Ibrahim M, Ayad H, Mahdi MAH. 1934. The new treatment of obesity with dinitro-o-cresol or Dekrysil. J Egypt Med Assoc 17:968–990.
*Ilivicky J, Casida JE. 1969. Uncoupling action of 2,4-dinitrophenols, 2-trifluoromethylbenzimidazoles, and certain other pesticide chemicals upon mitochondria from different sources and its relation to toxicity. Biochem Pharmacol 18:1389–1401.5799112
*Ingebrigtsen K, Froslie A. 1980. Intestinal metabolism of DNOC and DNBP in the rat. Acta Pharmacol Toxicol (Copenh) 46:326–328.7376883
*IRIS. 2017. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/simple_list.cfm?list_type=alpha. March 2, 2017.
*Jafvert CT. 1990. Sorption of organic acid compounds to sediments: Initial model development. Environ Toxicol Chem 9:1259–1268.
*Jafvert CT, Westall JC, Grieder E, . 1990. Distribution of hydrophobic ionogenic organic compounds between octanol and water: Organic acids. Environ Sci Technol 24:1795–1803.
*James RH, Adams RE, Finkel JM, . 1984. Evaluation of analytical methods for the determination of POHC in combustion Products. In: Proceedings of the 77th Air Pollution Control Association annual meeting, San Francisco, CA, June 24-29, 1984. Paper 84-18.5, l-25.
Jegatheeswaran T, Harvey DG. 1970. Metabolism of DNOC in sheep. Vet Ret 87:19–20.
*Jensen HL, Gundersen K. 1955. Biological decomposition of aromatic nitro-compounds. Nature 4451:341.
*Jensen HL, Lautrup-Larsen G. 1967. Microorganisms that decompose nitro-aromatic compounds, with special reference to dinitro-o-cresol. Acta Agriculturae Scandinavica 17:115–126.
*Jones KH, Sanderson DM, Noakes DN. 1968. Acute toxicity data for pesticides (1968). World Review of Pest Control 7:135–143.
*Kadenczki L, Arpad Z, Gardi I, . 1992. Column extraction of residues of several pesticides from fruits and vegetables: A simple multiresidue analysis method. J AOAC Int 75(1):53–61.
*Kaufman DD. 1976. Phenols. In: Kearney PC, Kaufman DD, eds. Herbicides: chemistry, degradation, and mode of action. Volume 2. 2nd edition. New York: Marcel Dekker, Inc., 665–707.
Kearney PC, Kaufman DD, eds. 1976. Herbicides: Chemistry, degradation, and mode of action. 2^nd^ ed. New York: Marcel Dekker, Inc.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
*Keplinger MC, Lanier GE, Deichmann WB. 1959. Effects of environmental temperature on the acute toxicity of a number of compounds in rats. Toxicol Appl Pharmacol 1:156–161.13635685
*Kincannon DF, Lin YS. 1985. Microbial degradation of hazardous wastes by land treatment. Proceedings of the Industrial Waste Conference 40:607–619.
*King E, Harvey DG. 1953a. Some observations on the absorption and excretion of 4,6-dinitro-o-cresol (DNOC). 1. Blood dinitro-o-cresol levels in the rat and the rabbit following different methods of absorption. Biochem J 53:185–195.13032053
*King E, Harvey DG. 1953b. Some observations on the absorption and excretion of 4:6-dinitro-o-cresol. 2. The elimination of 4:6-dinitro-o-cresol by man and animals. Biochem J 53:196–200.13032054
*King E, Harvey DG. 1954. On the metabolism of some aromatic nitro-compounds by different species of animal. Part 1. Some factors influencing the elimination of 4,6-dinitro-o-cresol from the blood of the rat. J Pharm Pharmacol 6:529–533.13184431
Klaassen CD. 1990. Nonmetallic environmental toxicants air pollutants solvents and vapors and pesticides. In: Gilman AG, ., eds. Goodman and Gilman’s The pharmacological basis of therapeutics. 8th ed. Oxford, England: Pergamon Press, 1615–1639.
*Kloepffer W. 1992. Photochemical degradation of pesticides and other chemicals in the environment: A critical assessment of the state of the art. Sci Total Environ 123/124:145–159.
Kreczko S, Zwierz K, Jaroszewicz K. 1974. Glycoprotein biosynthesis by the guinea pig liver in chronic 4,6-dinitro-o-cresol poisoning. Acta Biol Acad Sci Hung 25(3):167–171.4466281
Kreczko S, Zwierz K, Kilczewska D. 1977. The activity of aspartate (E.C. 2.6.1.1) and alanine (E.C.2.6.1.2) aminotransferases in serum and liver in the chronic 4,6-dinitro-o-cresol poisoning of the guinea pig. Acta Med Acad Sci Hung 34:87–90.
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kuiper J, Hanstveit AO. 1988. Biodegradation rates of xenobiotic compounds in plankton communities. In: Capuzzo JM, Kester DR, eds. Oceanic processes in marine/communities. Vol 1: Biological processes and wastes in the ocean. Malabar, FL: Robert E. Kroeger Publishing Co., 79–88.
*Kurinnyi AI, Pilinskaya MA, German IV, . 1982. Implementation of a program of cytogenetic study of pesticides: Preliminary evaluation of cytogenetic activity and potential mutagenic hazard of 24 pesticides. Cytol Genet (England) 16:50–53.
*Lawford DJ, King E, Harvey DG. 1954. On the metabolism of some aromatic nitro-compounds by different species of animals. Part II: The elimination of various nitro-compounds from the blood of different species of animals. J Pharm Pharmacol 6:619–624.13192621
*Lecce JG. 1966. In vitro absorption of gamma-globulin by neonatal intestinal epithelium of the pig. J Physiol (Lond) 184:594–604.4164327
*Leegwater DC, Van der Greef J, Bos KD. 1982. Integrated studies on the metabolic fate of DNOC. II. Biotransformation in mammals. Meded Fat Landbouwwet, Rijksuniv Gent 47:401–408.
*Leuenberger C, Czuczwa J, Tremp J, . 1988. Nitrated phenols in rain: Atmospheric occurrence of phytotoxic pollutants. Chemosphere 175 11–5 15.
*Lisi P, Caraffini S, Assalve D. 1987. Irritation and sensitization potential of pesticides. Contact Dermatitis 17:212–218.2962818
*Locket S. 1970. Hemodialysis in the treatment of acute poisoning. Proc R Sot Med 63:427–430.
*Loehr RC. 1989. Project summary: Treatability potential for EPA listed hazardous wastes in soil. EPA600S289011. Ada OK: U.S. Environmental Protection Agency, Robert S. Kerr Environmental Research Lab.
*Loehr RC, Krishnamoorthy R. 1988. Terrestrial bioaccumulation potential of phenolic compounds. Haz Waste Haz Mat 5:109–119.
*Lopez-Avila V, Bauer K, Milanes J, . 1993. Evaluation of Soxtec extraction procedure for extracting organic compounds from soils and sediments. J AOAC Int 76(4):864–880.
*McCormick NG, Feeherry FE, Levinson HS. 1976. Microbial transformation of 2,4,6-trinitrotoluene and other nitroaromatic compounds. Appl Environ Microbial 31:949–958.
*Merck. 1989. Dinitrocresol. In: The Merck index. 11^th^ ed. Rahway, NJ: Merck and Company, Inc., 3273.
*Metcalf RL. 1978. Insect control technology. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 13, 3rd ed. New York: John Wiley and Sons, 428.
*Mhalas JG, Tripathi AM, Rama Rao NV. 1989. Determination of 2,6- and 4,6-dinitrocresols by differential pulse polarography. Microchem J 40:251–256.
*Mueller J, Haberzettl R. 1980. Mutagenicity of DNOC in Drosophila melanogaster. Arch Toxicol Suppl 4:59–61.6776939
*Murphy SD. 1986. Toxic effects of pesticides. In: Klaasen DC, Amdur MO, Doull J, eds. Casarett and Doull’s toxicology. 3rd ed. New York: Macmillan, 519–581.
*Muscatello U, Guarriero-Bobyleva V, Pasquali-Ronchetti I, . 1975. Configurational changes in isolated rat liver mitochondria as revealed by negative staining. III. Modifications caused by uncoupling agents. J Ultrastruct Res 52:2–12.
*Nagy ZS, Mile I, Antoni F. 1975. Mutagenic effect of pesticides on Escherichia coli WP2 try. Acta Microbial Acad Sci Hung 22:309–314.
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NATICH. 1992. National Toxics Information Clearinghouse. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC, and State and Territorial Air Pollution Program Administrators/Association of Local Air Pollution Control Officials. September 1991. NTIS PB92143700, 4–202.
*Nehéz M, Paddy A, Selypes A, . 1981. The teratogenic and mutagenic effects of dinitro-o-cresol-containing herbicide on the laboratory mouse. Ecotoxicol Environ Safety 5:38–44.7472254
*Nehéz M, Selypes A, Mazzag E, . 1984. Additional data on the mutagenic effect of dinitro-o-cresol-containing herbicides. Ecotoxicol Environ Safety 875–879.
*Nehéz M, Selypes A, Paldy A, . 1978a. Recent data on the examination of the mutagenic effect of a dinitro-o-cresol-containing pesticide by different test methods. Ecotoxicol Environ Safety 21:243–248.
*Nehéz M, Selypes A, Paldy A, . 1978b. The mutagenic effect of a dinitro-o-cresol-containing pesticide on mice germ cells. Ecotoxicol Environ Safety 2:401–405.751792
*Nehéz M, Selypes A, Paldy A, . 1982. The effects of five weeks treatment with dinitro-o-cresol- or trifluralin-containing pesticides on the germ cells of male mice. J Appl Toxicol 2(4):179–180.7185898
Nendza M, Seydel JK. 1988. Quantitative structure-toxicity relationships for ecotoxicologically relevant biotest systems and chemicals. Chemosphere 17:1585–1602.
NIOSH. 1978. Criteria for a recommended standard: Occupational exposure to dinitro-ortho-cresol Report. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 78-131. PB80175870, 159.
*NIOSH. 1984. Method 5166, Dinitro-o-cresol. In: Eller PM, ed. NIOSH Manual of Analytical Methods, 3rd Edition. Volume 1. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service. National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 84-100.
NIOSH. 1987. Registry of toxic effects of chemical substances 1985-86, Vol. 2. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 1692–1693.
NIOSH. 1990. NIOSH pocket guide to chemical hazards. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service Centers for Disease Control, National Institute for Occupational Safety and Health, 148.
NIOSH. 1992. NIOSH recommendations for occupational safety and health: Compendium of policy documents and statement. National Institute for Occupational Safety and Health, Cincinnati, OH. NTIS PB92162536, 76.
*NIOSH. 1994. Dinitro-o-cresol. NIOSH pocket guide to chemical hazards. Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/534521.html. June 16, 2017.
*NIOSH. 2016. Dinitro-o-cresol. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0234.html. June 16, 2017.
*Nishimura N, Nishimura H, Oshima H. 1982. Survey on the mutagenicity of pesticides by the Salmonella microsome test. Aichi Ika Daigaku Igakkai Zasshi 10(4):305–312.
*NTDB. 1994. The National Trade Data Bank. Washington, DC: U.S. Department of Commerce, Economics and Statistics Administration (CD-ROM).
*NTP. 2016. Report on Carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. February 28, 2017.
*O’Connor OA, Young LY. 1989. Toxicity and anaerobic biodegradability of substituted phenols under methanogenic conditions. Environ Toxicol Chem 8:853–862.
*Ong CP, Lee HK, Li SFY. 1992. Supercritical fluid chromatographic separation of 11 priority phenols using chlorodifluoromethane as modifier. J Chromatogr Sci 30:319–23.
*Ong CP, Ng CL, Chong NC, . 1991. Analysis of priority substituted phenols by micellar electrokinetic chromatography. Environ Monitoring and Assessment 19:93–103.
OSHA. 1989. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1993. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 2016a. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-438. April 1990.
*Parent-Massin D, Thouvenot D. 1993. In vitro study of pesticide hematotoxicity in human and rat progenitors. J Pharmacol Toxicol Methods 30/4: 203–207.
*Parker VH. 1949. Method for the routine estimation of 3:5-dinitro-o-cresol (DNOC). Analyst 74:646–647.15400355
*Parker VH, Barnes JM, Denz FA. 1951. Some observations on the toxic properties of 3:5-dinitro-ortho-cresol. Br J Ind Med 8:226–235.14878957
*Patterson JW, Kodukala PS. 1981. Biodegradation of hazardous organic pollutants. Chemical Engineering Progress 77:48–55.
*Perez C, Soderholm SC. 1991. Some chemicals requiring special consideration when deciding whether to sample the particle, vapor, or both phases of an atmosphere. Appl Occup Environ Hyg 6(10):859–864.
*Plimmer JR. 1976. Volatility. In: Kearney PC, Kaufman DD, eds. Herbicides: Chemistry degradation and mode of action. Vol. 2, 2nd ed. New York: Marcel Dekker Inc., 891–934.
*Plotz M. 1936. Dinitro-ortho-cresol. A metabolic stimulator and its toxic side-actions. N Y State J Med 41:266–268.
*Pohland FG, Shaffer TR, Yari S, . 1987. Fate of selected organic pollutants during landfill disposal operations. U.S. Army Medical Research and Development Company, Fort Detrick, Frederick, MD. 16, ADA 100-117.
*Pollard AB, Filbee JF. 1951. Recovery after poisoning with di-nitro-ortho-cresol. Lancet 2:618–619.
*Porschmann J, Stottmeister U. 1993. Methodical investigation of interactions between organic pollutants and humic organic material in coal wastewaters. Chromatographia 36:207–211.
*Pospisil PA, Marcus MF, Kobus MA. 1992. The application of supercritical fluid capillary chromatography to the analysis of Appendix-VIII and IX compounds. ASTM Spec Tech Publ. STP 1075 Wa 154-169.
Potts GR. 1973. Pesticides and the fertility of the grey partridge, Perdix perdix. J Reprod Fertil Suppl 19:391–402.4522386
*Pugh PM, Stone SL. 1968. The effect of 2,4-dinitrophenol and related compounds on bile secretion. J Physiol (Lond) 198:39–49.5677031
*Quick HE. 1937. Slimming drugs and cataract with notes of a case. Br Med J 1:1203–1204.20780727
*Quinto I, De Marinis E, Mallardo M, . 1989. Effect of DNOC, ferbam, and imidan exposure on mouse sperm morphology. Mutat Res 224:405–408.2555709
Raetz KH, Mattheus A, Heise H, . 1079. [Effect of a dinitrocresol-containing herbicide (Hedolit) on human reproduction.] Dermatol Monatsschr 165:658–664. (German)
*Remondelli P, Mugnoz B, Della Morte R, . 1986. Evaluation of the mutagenic potential of thirteen pesticides by measuring both his+ and HGPRT-deficient mutants in Salmonella typhimurium. Med Biol Environ 14:377–386.
*Roseboom H, Wammes JIJ, Wegman RCC. 1981. Determination of nitrophenol derivatives in various crops by reversed-phase ion-pair high-performance liquid chromatography. Anal Chim Acta 132:195–199.
*San RHC, Rosin MP, See RH, . 1989. Use of urine for monitoring human exposure to genotoxic agents. In: Biological monitoring for pesticide exposure: Measurement, estimation, and risk reduction. ACS Symposium Series 382:98–116.
*Schneider JF, Schneider KR, Spiro SE, . 1991. Evaluation of gas chromatography/matrix isolation-infrared spectroscopy for the quantitative analysis of environmental samples. Appl Spectrosc 45(4):566–571.
*Schroeder SA, McPhee SJ. 1990. Malignant hyperthermia. In: Schroeder SA, Krupp MA, Tierney LM, ., eds. Current medical diagnosis and treatments. Norwalk, CT: Appleton and Lange, 172.
*Schroeder WH, Dobson M, Kane DM, . 1987. Toxic trace elements associated with airborne particulate matter: A review. J Air Pollut Control Assoc 37:1267–1285.
*Schwarzenbach RP, Stierli R, Folsom BR, . 1988. Compound properties relevant for assessing the environmental partitioning of nitrophenols. Environ Sci Technol 22:83–92.22195514
*Shafik TM, Sullivan HC, Enos HR. 1973. Multiresidue procedure for halo- and nitrophenols. Measurements of exposure to biodegradable pesticides yielding these compounds as metabolites. J Agric Food Chem 21:295–298.4688914
*Shen TT. 1982a. Estimation of organic compound emissions from waste lagoons. J Air Pollut Control Assoc 32(1):79–82.
*Shen TT. 1982b. Air quality assessment for land disposal of industrial wastes. Environ Management 6(4):297–305.
*Sherma J. 1991. Thin layer chromatography of pesticides. J Planar Chromatogr 4(Jan/Feb):7–14.
*Smith JN, Smithies RH, Williams RT. 1953. Studies in detoxication: Urinary metabolites of 4,6-dinitro-o-cresol in the rabbit. Biochem J 54:225–237.13058863
*Somani, SM, Schaeffer, DJ, Mack, JO. 1981. Quantifying the toxic and mutagenic activity of complex mixtures with Salmonella typhimurium. J Toxicol Environ Health 7:643–653.7026798
*Sovljanski M, Popovic D, Tasic M, . 1971. Intoxications with dinitroorthocresol. Arh Hig Rada Toksikol 22:329–332.5161371
*Spanggord RJ, Gibson BW, Keck RG, . 1982a. Effluent analysis of wastewater generated in the manufacture of 2,4,6-trinitrotoluene. I. Characterization study. Environ Sci Technol 16(4):229–232.
*Spanggord RJ, Mortelmans, KE, Griffin, AP, . 1982b. Mutagenicity in Salmonella typhimurium and structure-activity relationships of wastewater components emanating from the manufacture of trinitrotoluene. Environ Mutagen 4:163–179.7042329
*Spencer HC, Rowe VK, Adams EM, . 1948. Toxicological studies on laboratory animals of certain alkyldinitrophenols used in agriculture. J Ind Hygiene Toxicol 30:10–25.
SRI. 1992. 1992 Directory of chemical producers. United States of America. Menlo Park, CA: Stanford Research Institute, International.
SRI. 1994. 1994 Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute, International, 584.
*Starek A, Lepiarz W. 1974. Influence of some fats on 4,6-dinitro-o-cresol (DNOC) resorption from alimentary tract of rats. Pol J Pharmacol Pharm 26:485–491.4427808
*Steer C. 1951. Death from di-nitro-ortho-cresol. Lancet 1:1419.
*Stoner HB. 1969. Studies on the mechanism of shock: The effect of trauma on the toxicity of 3,5 dinitro-o-cresol and sodium fluoroacetate. Br J Exp Pathol 50:277–284.5792903
*Stott H. 1956. Polyneuritis after exposure to dinitro-o-cresol. Br Med J 1:900–901.13304372
Strube K, Janke D, Kappler R, . 1991. Toxicity of some herbicides to in vitro growing tobacco pollen tubes (the pollen test). Environ Exp Botany 31:217–222.
*Stutz DR, Janusz SJ. 1988. Hazardous material injuries: A handbook for pre-hospital care, 2nd ed. Beltsville MD: Bradford Communications Corp.
*Sundvall A, Marklund H, Rannug U. 1984. The mutagenicity on Salmonella typhimurium of nitrobenzoic acids and other wastewater components generated in the production of nitrobenzoic acids and nitrotoluenes. Mutat Res 137:71–78.6381997
*Suntio LR, Shiu WY, Mackay D. 1988. Critical review of Henry’s law constants for pesticides. Rev Environ Contam Toxicol 103:1–59.
*Tabak HH, Chambers CW, Kabler PW. 1964. Microbial metabolism of aromatic compounds. I. Decomposition of phenolic compounds and aromatic hydrocarbons by phenol-adapted bacteria. J Bacterial 87:910–919.
*Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
*Tainter ML, Bergstrom FW, Cutting WC. 1935. Metabolic activity of compounds related to dinitrophenol. J Pharmacol Exp Ther 53:58–66.
*Takahashi KL, Hojo H, Aoyama H, . 2004. Comparative studies on the spermatotoxic effects of dinoseb and its structurally related chemicals. Reprod Toxicol 18(4):581–588. 10.1016/j.reprotox.2004.02.009.15135852
*Takahashi KL, Takahashi N, Hojo H, . 2006. Pathogenetic transition in the morphology of abnormal sperm in the testes and the caput, corpus, and cauda epididymides of male rats after treatment with 4,6-dinitro-o-cresol. Reprod Toxicol 22(3):501–507. 10.1016/j.reprotox.2006.03.018.16713173
*Tesic D, Terzic LJ, Dimitrijevic B, . 1972. Experimental investigation of the effect of environmental temperature and some medicaments on the toxic effect of dinitroorthocresol. Acta Vet (Beogr) 22:45–52.
*Tewfik MS, Evans WC. 1966. The metabolism of 3,5-dinitro-o-cresol (DNOC) by soil microorganisms. Biochem J 99:31–32.
*Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15–21.
*Thorn NS, Agg AR. 1975. The breakdown of synthetic organic compounds in biological processes. Proc R Sot Lond [Biol] 189:347–357.
*Tratnyek PG, Holgne J. 1991. Oxidation of substituted phenols in the environment: A QSAR analysis of rate constants for reaction with singlet oxygen. Environ Sci Technol 25:1596–1604.
*Tremp J, Czuczwa J, Leuenberger C, . 1986. Nitrated phenols in rain. ACS Symposium Series 26, 142–143.
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency, Office of Information Analysis and Access. Office of Environmental Information. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
*Tripathi AM, Mhalas JG, Rama-Rao NV. 1989. Determination of 2,6 and 4,6-Dinitrocresols by high performance liquid chromatography on a beta-cyclodextrin bonded column. J Chromatogr 466:442–445.
*Truhaut R, De Lavaur E. 1967. [Metabolism of 4,6-dinitro-o-cresol in rabbits.] C R Seances Acad Sci [D] 264:1937–1940. (French)
*U.S. Congress. 1990. Clean Air Act Amendments of 1990. 42 U.S. Code 7412, Title 1, Part A, Sec. 112.53, 826-827:
*Van den Berg KJ, Van Raaij JAGM, Bragt PC, . 1991. Interactions of halogenated industrial chemicals with transthyretin and effects on thyroid hormone levels in vivo. Arch Toxicol 65:15–19.2043046
*van der Greel J, Leegwater DC. 1983. Urine profile analysis by field desorption mass spectrometry, a technique for detecting metabolites of xenobiotics. Biomed Mass Spec 10(1):1–4.
*van Noort HR, Mandema E, Christensen EKJ, . 1960. [Dinitro-ortho-cresol intoxication in sprayers.] Ned Tidschr Geneeskd 104:676–684. (Dutch)
*Varnai 1, Kote G. 1969. [Forensic medical problems of mass ‘Krezonit’ poisoning.] Ned Tijdschr Geneeskd 104:676–684. (Hungarian)
*Vashakidze VI. 1967. [Some problems of the mechanism of action of pesticide (Granosan, Sevin, DNOC) on the reproductive sphere of experimental animals.] Soobshch Akad Nauk Gruz SSR 48:219–224. (Russian)
*Verschoyle RD, Brown AW, Ray DE, . 1987. The relationship between uncoupling of oxidative phosphorylation and neuronal necrosis within the CNS in rats dosed with trihalogenated imidazoles. Toxicol Appl Pharmacol 89:175282.
*Vos JG, Krajnc EI, Beekhof PK, . 1983. Methods for testing immune effects of toxic chemicals: Evaluation of the immunotoxicity of various pesticides in the rat. In: Proceedings of the 5th Pesticide Chemistry: Human Welfare in the Environment International Congress, Vol 3, 497–504.
*Wallnoefer PR, Ziegler W, Engelhart J, . 1978. Transformation of dinitrophenol herbicide by Azobacter sp. Chemosphere 12:967–972.
*Wanner O, Egil T, Fleischman T, . 1989. Behavior of the insecticides disulfoton and thiometon in the Rhine river: A chemodynamic study. Environ Sci Technol 23:1232–1242.
*Weast RC, ed. 1985. Handbook of chemistry and physics, 66th ed. Boca Raton, FL: CRC Press, Inc.
*Weber JB. 1972. Interaction of organic pesticides with particulate matter in aquatic and soil systems. Adv Chem Series 111:55–120.
*WHO. 1975. World Health Organization. Chemical and biochemical methodology for the assessment of hazards of pesticides for man. WHO Tech Rep Ser 560:5–27.
WHO. 1982. World Health Organization. Recommended health-based limits in occupational exposure to pesticides. WHO Tech Rep Ser 677:1–110.
*WHO. 2000. Dinitro-ortho-cresol. Environmental Health Criteria 220. Geneva, Switzerland: World Health Organization. http://www.who.int/iipcs/publications/ehc/en/ehc220.pdf. May 25, 2017.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Williams PP. 1977. Metabolism of synthetic organic pesticides by anaerobic microorganisms. Residue Rev 66:63–135.335464
*Williamson RL, Metcalf RL. 1967. Salicylanilides: A new group of active uncouplers of oxidative phosphorylation. Science 1581694–1695.
*Wolfe HR. 1976. Field exposure to airborne pesticides. In: Lee RI Jr, ed. Air pollution from pesticides and agricultural processes. Cleveland OH: CRC Press, 137–163.
Wolfe HR, Durham WF, Armstrong JF. 1967. Exposure of workers to pesticides. Arch Environ Health 14:622–633.6024487
*Worthing CR. 1987. The pesticide manual. 8th ed. Suffolk, England: The Lavenham Press Ltd., 326–327.
*Yao S, Meyer A, Henze G. 1991. Comparison of amperometric and UV-spectrophotometric monitoring in the HPLC analysis of pesticides. Fresenius J Anal Chem 339:207–211.
Yoder J, Watson M, Benson WW. 1973. Lymphocyte chromosome analysis of agricultural workers during extensive occupational exposure to pesticides. Mutat Res 21:335–340.4779319
*Zahn R, Wellens H. 1980. [Examination of biological degradability through the batch method2further experience and new possibilities of usage.] Z Wasser Abwasser Forsch 13:1–7. (German)