# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Jessilynn Taylor, M.S., CDR USPHS
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- David W. Wohlers, Ph.D.
- SRC, Inc., North Syracuse, NY