# VERSION HISTORY

Date | Description
August 1995 | Draft for public comment toxicological profile released
October 2009 | Addendum to the toxicological profile released
January 2018 | Update of data in Chapters 2, 3, and 7