# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding dinitrocresols in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for dinitrocresols.

Table 7-1 Regulations and Guidelines Applicable to Dinitrocresols

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2017
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No data | EPA 2012
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | RfD | No data | IRIS 2017
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | EAFUS | No data^a^ | FDA 2013
Cancer
ACGIH | Carcinogenicity classification | No data | ACGIH 2016
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | No data | IRIS 2017
IARC | Carcinogenicity classification | No data | IARC 2017
Occupational
ACGIH | TLV | | ACGIH 2016
ACGIH | DNOC | 0.2 mg/m^3^ ^b^ | ACGIH 2016
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | | OSHA 2016a, 2016b, 2016c
OSHA | DNOC | 0.2 mg/m^3^ ^b^ | OSHA 2016a, 2016b, 2016c
NIOSH | REL (up to 10-hour TWA) | | NIOSH 1994, 2016
NIOSH | DNOC | 0.2 mg/m^3^ ^b^ | NIOSH 1994, 2016
NIOSH | IDLH | | NIOSH 1994, 2016
NIOSH | DNOC | 5 mg/m^3c^ | NIOSH 1994, 2016
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
AIHA | ERPGs | No data | AIHA 2015
DOE | PACs-air | | DOE 2016a
DOE | DNOC | | DOE 2016a
DOE | PAC-1^d^ | 0.6 mg/m^3^ | DOE 2016a
DOE | PAC-2^d^ | 0.83 mg/m^3^ | DOE 2016a
DOE | PAC-3^d^ | 5 mg/m^3^ | DOE 2016a

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Skin notation: potential significant contribution to the overall exposure by the cutaneous route.

c Based on acute toxicity data in humans and animals.

d Definitions of PAC terminology are available from DOE (2016b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; DNOC = 4,6-dinitro-o-cresol; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentrations; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization