# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for selected dinitrocresols.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of dinitrocresols.

Table 4-1 Chemical Identity of Dinitrocresols

Chemical name | 4,6-Dinitro-m-cresol | 4,6-Dinitro-o-cresol^a^ | 3,5-Dinitro-o-cresol | 2,6-Dinitro-p-cresol^a^
Synonym(s) and registered trade name(s) | 2,4-Dinitro-5-methylphenol; 3-methyl-4,6-dinitrophenol | DNOC; DNC; 3,5-dinitro-2-hydroxytoluene; 2-methyl-4,6-dinitrophenol; Antinonnin; Detal; Dinitrol; Effusan; Selinon; others^b^ | 2-Methyl-3,5-dinitrophenol | DNPC; 3,5-dinitro-4-hydroxy toluene; Victoria Orange; Victoria Yellow
Chemical formula | C_7_H_6_N_2_O_5_ | C_7_H_6_N_2_O_5_ | C_7_H_6_N_2_O_5_ | C_7_H_6_N_2_O_5_
Chemical structure | [image] | [image] | [image] | [image]
CAS Registry Number | 616-73-9 | 534-52-1 | 497-56-3 | 609-93-8

a All information obtained from ChemID 1993 and HSDB 1994 except where noted.

b Merck 1989.

CAS = Chemical Abstracts Service

Table 4-2 Physical and Chemical Properties of Dinitrocresols

Chemical name | 4,6-Dinitro-m-cresol | 4,6-Dinitro-o-cresol^a^ | 3,5-Dinitro-o-cresol^b^ | 2,6-Dinitro-p-cresol^c^
Molecular weight | 198.13 | 198.13 | 198.13 | 198.13
Color | No data | Yellow | Yellow | Yellow
Physical state | No data | Solid | Solid | Solid
Melting point | No data | 87.5°C; 86.5°C^d^ | 85.8°C | 80–81°C; 85°C^d^
Boiling point | No data | 312°C^e^ | No data | No data
Density | No data | No data | 1.49 g/cm^3^ ^f^ | No data
Odor | No data | Odorless^g^ | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
pK_a_ | No data | 4.46^h^; 4.38^i^; 4.35^j^ | No data | No data
Solubility:
Water | No data | 130 mg/L at 15°C^k^ | No data | 290 mg/L
Organic solvents | No data | Soluble in ethanol (4.3 g/100 g), acetone (100 g/100 g), and benzene (37 g/100 g)^g^ | Soluble in ether, ethanol, and acetone^d^ | Soluble in ether, ethanol, and acetone^d^
Partition coefficients:
Log K_ow_ | No data | 2.12^l^, 2.56^m^, 2.16^i^, 2.85^n^ | No data | No data
Log K_oc_ | No data | 2.35–2.77^a,o^ | No data | No data
Vapor pressure | No data | 1.05x10^-4^ mmHg at 25°C^p^; 3.6x10^-4^ mmHg at 35°C^r,s^ | 5.2x10^-5^ mmHg at 20°C^q^ | No data
Henry’s law constant | No data | 1.4x10^-6^ atm-m^3^/mol at 25°C^t,u^ | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | 1 mg/m^3^ = 0.12 ppm | 1 mg/m^3^ = 0.12 ppm | 1 mg/m^3^ = 0.12 ppm | 1 mg/m^3^ = 0.12 ppm
Explosive limits | No data | No data | No data | No data

a All information obtained from Merck 1989 unless otherwise noted.

b All information obtained from Lide 1993 unless otherwise noted.

c All information obtained from EPA 1988a unless otherwise noted.

d Lide 1993.

e ACGIH 1986.

f Bailey and White 1965 (no temperature value given).

g Metcalf 1978.

h Cessna and Grover 1978.

i Jafvert et al. 1990.

j Weber 1972.

k Meister 1991.

l Schwarzenbach et al. 1988.

m GEMS 1986.

n Loehr and Krishnamoorthy 1988.

o Kenaga 1980.

p Suntio et al. 1988.

q EPA 1979.

r Plimmer 1976.

s Hamaker and Kerlinger 1969.

t Shen 1982a.

u Shen 1982b.