# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Dinitrocresols Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrocresols
CAS Numbers: | 534-52-1; 616-73-9; 497-56-3; 609-93-8
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of acute-duration inhalation MRLs.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans occupationally exposed to DNOC, exposure probably involved both the inhalation and dermal routes, and exposure concentrations were not known. Only one study was located regarding health effects in animals after inhalation exposure to DNOC. In this study, rats exposed to 0.1 or 100 mg/m^3^ DNOC for 4–5 hours were lethargic, and rats exposed to 100 mg/m^3^ had increased respiratory rates and body temperatures (King and Harvey 1953a). No NOAEL was identified, and other endpoints were not evaluated. Therefore, data are insufficient to derive MRLs for inhalation exposure to DNOC.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS

## Dinitrocresols Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrocresols
CAS Numbers: | 534-52-1; 616-73-9; 497-56-3; 609-93-8
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of intermediate-duration inhalation MRLs.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans occupationally exposed to DNOC, exposure probably involved both the inhalation and dermal routes, and exposure concentrations were not known. Only one study was located regarding health effects in animals after inhalation exposure to DNOC. In this study, rats exposed to 0.1 or 100 mg/m^3^ DNOC for 4–5 hours were lethargic, and rats exposed to 100 mg/m^3^ had increased respiratory rates and body temperatures (King and Harvey 1953a). No NOAEL was identified, and other endpoints were not evaluated. Therefore, data are insufficient to derive MRLs for inhalation exposure to DNOC.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS

## Dinitrocresols Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrocresols
CAS Numbers: | 534-52-1; 616-73-9; 497-56-3; 609-93-8
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of chronic-duration inhalation MRLs.

Rationale for Not Deriving an MRL: Although health effects have occurred in humans occupationally exposed to DNOC, exposure probably involved both the inhalation and dermal routes, and exposure concentrations were not known. Only one study was located regarding health effects in animals after inhalation exposure to DNOC. In this study, rats exposed to 0.1 or 100 mg/m^3^ DNOC for 4–5 hours were lethargic, and rats exposed to 100 mg/m^3^ had increased respiratory rates and body temperatures (King and Harvey 1953a). No NOAEL was identified, and other endpoints were not evaluated. Therefore, data are insufficient to derive MRLs for inhalation exposure to DNOC.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS

## 4,6-Dinitro-o-cresol (DNOC) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,6-Dinitro-o-cresol (DNOC)
CAS Numbers: | 534-52-1
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.004 mg/kg/day
Critical Effect: | Excessive perspiration, fatigue, and dizziness
Reference: | Plotz 1936
Point of Departure: | LOAEL of 0.35 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 4
Species: | Human

MRL Summary: An acute-duration oral MRL of 0.004 mg/kg/day was derived for DNOC based on excessive perspiration, fatigue, and dizziness in a human who took DNOC for the purpose of weight reduction (Plotz 1936). The MRL is based on a LOAEL of 0.35 mg/kg/day and a total uncertainty factor of 100 (10 for use of a LOAEL and 10 for human variability).

Selection of the Critical Effect: Five healthy male volunteers weighing 59–81.4 kg who received 75 mg/day of DNOC (0.92–1.27 mg/kg/day) on 5 consecutive days experienced lassitude, headache, and malaise (Harvey et al. 1951). Two of an unspecified number of human subjects who received 3 mg/kg/day of DNOC had a 70–100% increase in metabolic rate within 3 days, and a slight increase in pulse rate, sweating, lethargy, headache, loss of appetite, and definite greenish-yellow pigmentation of the conjunctivae (Dodds and Robertson 1933).

In a case report of 15 patients who received 50 mg of DNOC/day (average dose consumed 1.05 mg/kg/day for 14–63 days), the average amount of weight loss was 0.45 kg/week (Ibrahim et al. 1934). DNOC caused an increase in basal metabolic rate, excessive perspiration, thirst, and fatigue. Yellow pigmentation of the conjunctivae occurred in all cases. Thus, it appears that some individuals were able to tolerate higher doses of DNOC for longer periods of time before developing symptoms. For this reason, the acute oral LOAEL of 0.35 mg/kg/day was considered to be an appropriate basis for the intermediate-duration MRL as well as for the acute-duration MRL. Animal studies all used higher doses of DNOC than human studies. Toxicokinetic studies indicate that humans tend to accumulate DNOC to a greater extent and eliminate DNOC more slowly than animals (King and Harvey 1953b). Furthermore, the use of DNOC as a weight-reducing drug in humans was carried out under medical supervision, and information on actual doses and durations were available. Therefore, the LOAEL of 0.35 mg/kg/day for excessive perspiration, fatigue, and dizziness was selected as the critical effect.

Selection of the Principal Study: The study of Plotz (1936) provided the lowest adverse effect level data for humans.

Summary of the Principal Study:

Plotz M. 1936. Dinitro-ortho-cresol. A metabolic stimulator and its toxic side-actions. N Y State J Med 41:266–268.

Three human subjects were administered DNOC for the purpose of weight reduction; the investigator took DNOC in a self-experiment as well. One subject received 0.75 mg/kg/day for 3 days, but experienced elevated body temperature, fatigue, and dizziness after 2 days. After a 2-week period without DNOC exposure, treatment was resumed at 0.35 mg/kg/day, and the subject complained of excessive perspiration, fatigue, and dizziness on the 7th day. The average doses taken by the other patients and the investigator were 0.58–1.0 mg/kg/day for periods of 4–11 weeks. Basal metabolic rate, pulse, blood pressure, body temperature, and body weight were monitored. Signs of toxicity included marked palpitations, elevated pulse rate, elevated body temperature, excessive perspiration, fatigue, lassitude, headache, a greenish tinge to the sclerae, and maculopapular, urticarial eruptions.

Selection of the Point of Departure for the MRL: The LOAEL of 0.35 mg/kg/day for excessive perspiration, fatigue, and dizziness was selected as the point of departure for deriving an MRL for acute-duration oral exposure to DNOC.

Calculations: None.

Uncertainty Factor: The LOAEL of 0.35 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for use of a LOAEL
- 10 for human variability

- MRL = LOAEL ÷ uncertainty factors
  - 0.35 mg/kg/day ÷ (10 × 10) = 0.004 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: See Selection of the Critical Effect above.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS

## 4,6-Dinitro-o-cresol (DNOC) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,6-Dinitro-o-cresol (DNOC)
CAS Numbers: | 534-52-1
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.004 mg/kg/day
Critical Effect: | Excessive perspiration, fatigue, and dizziness
Reference: | Plotz 1936
Point of Departure: | LOAEL of 0.35 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 4
Species: | Human

MRL Summary: An intermediate-duration oral MRL of 0.004 mg/kg/day was derived for DNOC based on excessive perspiration, fatigue, and dizziness in a human who took DNOC for the purpose of weight reduction (Plotz 1936). The MRL is based on a LOAEL of 0.35 mg/kg/day and a total uncertainty factor of 100 (10 for use of a LOAEL and 10 for human variability).

Selection of the Critical Effect: : Five healthy male volunteers weighing 59–81.4 kg who received 75 mg/day of DNOC (0.92–1.27 mg/kg/day) on 5 consecutive days experienced lassitude, headache, and malaise (Harvey et al. 1951). Two of an unspecified number of human subjects who received 3 mg/kg/day of DNOC had a 70–100% increase in metabolic rate within 3 days, and a slight increase in pulse rate, sweating, lethargy, headache, loss of appetite, and definite greenish-yellow pigmentation of the conjunctivae (Dodds and Robertson 1933).

In a case report of 15 patients who received 50 mg of DNOC/day (average dose consumed 1.05 mg/kg/day for 14–63 days), the average amount of weight loss was 0.45 kg/week (Ibrahim et al. 1934). DNOC caused an increase in basal metabolic rate, excessive perspiration, thirst, and fatigue. Yellow pigmentation of the conjunctivae occurred in all cases. Thus, it appears that some individuals were able to tolerate higher doses of DNOC for longer periods of time before developing symptoms. For this reason, the acute oral LOAEL of 0.35 mg/kg/day was considered to be an appropriate basis for the intermediate-duration MRL as well as for the acute-duration MRL. Animal studies all used higher doses of DNOC than human studies. Toxicokinetic studies indicate that humans tend to accumulate DNOC to a greater extent and eliminate DNOC more slowly than animals (King and Harvey 1953b). Furthermore, the use of DNOC as a weight-reducing drug in humans was carried out under medical supervision, and information on actual doses and durations were available. Therefore, the LOAEL of 0.35 mg/kg/day for excessive perspiration, fatigue, and dizziness was selected as the critical effect.

Selection of the Principal Study: The study of Plotz (1936) provided the lowest adverse effect level data for humans.

Summary of the Principal Study:

Plotz M. 1936. Dinitro-ortho-cresol. A metabolic stimulator and its toxic side-actions. N Y State J Med 41:266–268.

Three human subjects were administered DNOC for the purpose of weight reduction; the investigator took DNOC in a self-experiment as well. One subject received 0.75 mg/kg/day for 3 days, but experienced elevated body temperature, fatigue, and dizziness after 2 days. After a 2-week period without DNOC exposure, treatment was resumed at 0.35 mg/kg/day, and the subject complained of excessive perspiration, fatigue, and dizziness on the 7th day. The average doses taken by the other patients and the investigator were 0.58–1.0 mg/kg/day for periods of 4–11 weeks. Basal metabolic rate, pulse, blood pressure, body temperature, and body weight were monitored. Signs of toxicity included marked palpitations, elevated pulse rate, elevated body temperature, excessive perspiration, fatigue, lassitude, headache, a greenish tinge to the sclerae, and maculopapular, urticarial eruptions.

Selection of the Point of Departure for the MRL: The LOAEL of 0.35 mg/kg/day for excessive perspiration, fatigue, and dizziness was selected as the point of departure for deriving an MRL for intermediate-duration oral exposure to DNOC.

Calculations: None.

Uncertainty Factor: The LOAEL of 0.35 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for use of a LOAEL
- 10 for human variability

- MRL = BMDL_05_ ÷ uncertainty factors
  - 0.35 mg/kg/day ÷ (10 × 10) = 0.004 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: See Selection of the Critical Effect above.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS

## Dinitrocresols Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dinitrocresols
CAS Numbers: | 534-52-1; 616-73-9; 497-56-3; 609-93-8
Date: | August 1995; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data from which to derive a chronic-duration oral MRL for DNOC.

Rationale for Not Deriving an MRL: There are no chronic-duration oral data for humans or animals.

Agency Contact (Chemical Manager): Jessilynn Taylor, M.S., CDR USPHS