# 9 REFERENCES

* cited in text

Acey R, Healy P, Unger TF, . 1987. Growth and aggregation behavior of representative phytoplankton as affected by the environmental contaminant di-n-butyl phthalate. Bull Environ Contam Toxicol 39:1–6.3607305
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1998. Documentation of the threshold limit values and biological exposure indices. 6th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 2000. Documentation of the threshold limit values and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agarwal DK, Lawrence WH, Nunez LJ, . 1985. Mutagenicity evaluation of phthalic acid esters and metabolites in Salmonella typhimurium cultures. J Toxicol Environ Health 16:61–69.3906141
Albaiges J, Casado F, Ventura F. 1986. Organic indicators of groundwater pollution by a sanitary landfill. Water Res 20:1153–1159.
*Albro PW, Moore B. 1974. Identification of the metabolites of simple phthalate diesters in rat urine. J Chromatogr 94:209–218.4844611
Albro PW, Jordan S, Corbett JT, . 1984. Determination of total phthalate in urine by gas chromatography. Anal Chem 56:247–250.6703327
Albro PW, Thomas R, Fishbein L. 1973. Metabolism of diethylhexyl phthalate by rats isolation and characterization of the urinary metabolites. J Chromatogr 76:321–330.4689606
*Allsopp M, Vianello G. 1992. Poly(vinyl chloride). In: Elvers B, Hawkins S, Schultz G, eds. Ullman’s Encyclopedia of Industrial Chemistry vol. A21. Weinheim Germany: VCH Vergsgesellschaft, 717–742.
*Al-Omran LA, Preston MR. 1987. The interactions of phthalate esters with suspended particulate material in fresh and marine waters. Environ Pollut 46:177–186.15092728
*Altman PL, Dittmer DS, eds. 1974. Biological handbooks: Biology data book. Vol. III 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008.
Amacher DE, Schomaker SJ, Burkhardt JE. 1998. The relationship among microsomal enzyme induction, liver weight and histological change in rat toxicology studies. Food Chem Toxicol 36:831–839.9737431
*Andersen ME, Kirshnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ 3rd, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Ashford R. 1994. Dibutyltin dichloride. In: Ashford R, ed. Ashford’s Dictionary of Industrial Chemicals. London, England: Wavelength Publications Ltd., 279.
*Astill BD. 1989. Metabolism of DEHP: Effects of prefeeding and dose variation, and comparative studies in rodents and the cynomolgus monkey (CMA studies). Drug Metab Rev 21(1):35–53.2696635
*Atlas E, Giam CS. 1981. Global transport of organic pollutants: Ambient concentrations in the remote marine atmosphere. Science 211:163–165.17757266
Atlas E, Velasco A, Sullivan K, . 1983. A radio tracer study of air-water exchange of synthetic organic compounds. Chemosphere 12:1251–1258.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
*Aurela B, Kulmala H, Söderhjelm L. 1999. Phthalates in paper and board packaging and their migration into Tenax and sugar. Food Addit Contam 16(12):571–577.10789379
Bakale G, McCreary RD. 1987. A physico-chemical screening test for chemical carcinogens: The k_e_ test. Carcinogenesis 8:253–264.3802409
*Barber ED, Astill BD, Moran EJ, . 1987. Peroxisome induction studies on seven phthalate esters. Toxicol Ind Health 3(2):7–22.3617071
*Barber ED, Cifone M, Rundell J, . 2000. Results of the L5178Y mouse lymphoma assay and the Balb/3T3 cell in vitro transformation assay for eight phthalate esters. J Anal Toxicol 20:69–80.
*Barber L. 1992. Hierarchical analytical approach to evaluating the transport and biogeochemical fate of organic compounds in sewage-contaminated groundwater, Cape Cod, MA. In: Lesage S, Jackson R, eds. Groundwater contamination and analysis at hazardous waste sites. New York NY: Marcel Dekker, Inc., 73–120.
*Barber LB, Thurman EM, Schroeder MP, . 1988. Long-term fate of organic micro pollutants in sewage-contaminated groundwater. Environ Sci Technol 22:205–211.19995023
*Barnes DG, Dourson M. 1988. Reference dose (RfD) Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Baue MJ, Herrmann R. 1997. Estimation of the environmental contamination by phthalic acid esters leaching from household wastes. Sci. Total Environ. 208:49–57.9496648
Bedding ND, McIntyre AE, Perry R, . 1982. Organic contaminants in the aquatic environment: 1. Sources and occurrence. Sci Total Environ 25:143–167.
*Bell FP. 1982. Effects of phthalate esters on lipid metabolism in various tissues, cells and organelles in mammals. Environ Health Perspect 45:41–50.7140695
*Berger G. 1994. Epidemiology of endometriosis. In: Nezhat CR, Berger GS, Nezhat CH, . eds. Modern surgical management of endometriosis. New York NY: Springer-Verlag.
Bernstein ME. 1984. Agents affecting the male reproductive system: Effects of structure on activity. Drug Metab Rev 15:941–996.6396061
*BIBRA. 1986. A 21 day feeding study of di-n-butyl phthalate to rats: Effects on the liver and liver lipids. Report to Chemical Manufacturers Association, Washington, DC. Carshalton, Surrey, UK: The British Industrial Biological Research Association. CMA Reference PE 28.0-BT-BIB.
*Bisesi MS. 1994. Esters. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. New York NY: John Wiley & Sons, Inc., 2967–3118.
*Blount BC, Milgram KE, Silva MJ, . 2000. Quantitative detection of eight phthalate metabolites in human urine using HPLC-APCI-MS/MS. Anal Chem 72:4127–4134.10994974
*BNA. 2001. Environment and safety: States and territories. Bureau of National Affairs. http://www.bna.com/. February 13, 2001.
Bove JL, Dalven P. 1981. A GC/MS method of determining airborne di-n-butyl- and di-(2-ethylhexyl) phthalates. Int J Environ Anal Chem 10:189–196.
*Bove JL, Dalven P, Kukreja VP. 1978. Airborne di-butyl and di-(2-ethylhexyl)-phthalate at three New York, NY: City air sampling stations. Int J Environ Anal Chem 5:189–194.
Bower RK, Haberman S, Minton PD. 1970. Teratogenic effects in the chick embryo caused by esters of phthalic acid. J Pharmacol Exp Ther 171:314–324.5459065
*Bruns-Weller E, Pfordt J. 2000a. [Determination of phthalic acid esters in foodstuffs and mother’s milk]. Z Ernahrungswiss 1(1):25–28. (German)
*Bruns-Weller E, Pfordt J. 2000b. [Determination of phthalic acid esters in foodstuffs, mother’s milk, dust, and textiles]. UmweltwissSchadst-Forsch 12(3):125–130. (German)
*Budavari S. 1996. n-Butyramide. In: Budavari S, O’Neil M, Smith S, . eds. The Merck index. Whitehouse Station NJ: Merck & Co., Inc., 1628.
Burmaster DE. 1982. The new pollution: Groundwater contamination. Environment 24:7–13, 33–36.
*Cadogan D, Howick C. 1992. Plasticizers. In: Elvers B, Hawkins S, Schultz G, eds. Ullmann’s encyclopedia of industrial chemistry. 5^th^ ed. Vol A20: Photography to plastics processing. Weinheim, Germany: VCH Verlagsgesellschaft, 439–457.
*Cadogan D, Howick C. 1996. Plasticizers. In: Kroschwitz J, Howe-Grant, eds. Kirk-Othmer encyclopedia of chemical technology. Vol 19. New York NY: John Wiley & Sons Inc., 258–290.
Cagianut B. 1954. Keratitis erosiva and nephritis toxica nach einnahme von dibutylphthalat. Schweiz Med Wochenschr 35:1243–1244.
Calnan CD. 1975. Dibutyl phthalate. Contact Dermatitis 1:388.
Cater BR, Cook MW, Gangolli SD. 1976. Zinc metabolism and dibutyl phthalate-induced testicular atrophy in the rat. Biochem Soc Trans 4:652–653.1001735
*Cater BR, Cook MW, Gangolli SD, . 1977. Studies on dibutyl phthalate-induced testicular atrophy in the rat: Effect on zinc metabolism. Toxicol Appl Pharmacol 41:609–618.918990
CCTTE. 1988. Computerized Listing of Chemicals Being Tested for Toxic Effects. Geneva, Switzerland: United Nations Environment Programme, International Programme on Chemical Safety, International Register of Potentially Toxic Chemicals. .
*CDC. 1999. Kansas. Center for Disease Control & Prevention. http://search.cdc.gov/shd/search2.html. May 25, 1999.
*Chan PKL, Meek ME. 1994. Di-n-butyl phthalate: Evaluation of risks to health from environmental exposure in Canada. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 12(2):257–268.
Chapin RE, Gulati D, Barnes L. 1997. Di-n-butyl phthalate, rats. Environ Health Perspect Suppl 105:249–250.
Chapin RE, Sloane RA, Haseman JK. 1998. Reproductive endpoints in general toxicity studies: Are they predictive? Reprod Toxicol 12:489–494.9717700
*Ching NP, Jham GN, Subbarayan C, . 1981a. Gas chromatographic-mass spectrometric detection of circulating plasticizers in surgical patients. J Chromatogr 222:171–177.7251735
Ching NP, Jham GN, Subbarayan C, . 1981b. Gas chromatographic quantitation of two plasticizers contaminating IV fluids stored in plastic containers. J Chromatogr B Biomed Sci Appl 225:196–201.
Chrostek WJ, Moshell AN. 1984. Health hazard evaluation report no. HETA 81-275-1122, General Telephone Company, York, Pennsylvania. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
Chung HY. 1999. Volatile components in crabmeats of charybdis feriatus. J Agric Food Chem 47:2280–2287.10794623
*CIS. 1999. The Chemical Information System. http://www.oxmol.com/prods/cis. May 24,1999.
Clansky KB, ed. 1986. Chemical guide to the OSHA hazard communication standard. Burlingame, CA: Roytech Publications, Inc., 57, 653–656.
Clark JR, Patrick JM Jr, Moore JC, . 1987. Waterborne and sediment-source toxicities of six organic chemicals to grass shrimp (Palaemonetes pugio) and amphioxus (Branchiostoma caribaeum). Arch Environ Contam Toxicol 16:401–407.3606200
Clayton GD, Clayton FE, eds. 1981. Patty’s industrial hygiene and toxicology third revised edition, volume 2A, toxicology. New York, NY: John Wiley and Sons, 2344–2347.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–113.3843496
CLPSD. 1988. Contract Laboratory Program Statistical Database. Viar and Company, Management Services Division. Alexandria, VA. December 22, 1988.
*Coldham NG, Dave M, Sauer MJ. 1998. Analysis of di-n-butyl phthalate biotransformation in cattle by liquid chromatography/ion trap mass spectrometry/mass spectrometry. J Mass Spectrom 33:803–810.9768498
*Colón I, Caro D, Bourdony CJ, . 2000. Identification of phthalate esters in the serum of young Puerto Rican girls with premature breast development. Environ Health Perspect 108(9):895–900.
Cook JC, Klinefelter GR, Hardisty JF, . 1999. Rodent leydig cell tumorigenisis: A review of the physiology, pathology, mechanisms, and relevance to humans. Crit Rev Toxicol 29(2):169–261.
*Cosmetic Ingredient Review Committee. 1985. Final report on the safety assessment of dibutyl phthalate, dimethyl phthalate, and diethyl phthalate. J Am Coll Toxicol 4(3):267–303.
Cote MG, Plaa GL, Valli VE, . 1985. Subchronic effects of a mixture of “persistent” chemicals found in the Great Lakes. Bull Environ Contam Toxicol 34:285–290.
Cripe CR, Walker WW, Pritchard PH, . 1987. A shake-flask test for estimation of biodegradability of toxic organic substances in the aquatic environment. Ecotoxicol Environ Saf 14:239–251.3691377
*Crump DR. 1995. Volatile organic compounds in indoor air. In: Hester RE, Harrison RM, ed. Volatile organic compounds in the atmosphere. Issues in environmental science and technology 4th ed. Cambridge: Royal Society of Chemistry, 109–124.
Cummings A, Gray LE Jr. 1987. Dibutyl phthalate: Maternal effects versus fetotoxicity. Toxicol Lett 39:43–50.3672555
Cummings A, Harris S. 1990. Identifying sites of maternally mediated early pregnancy loss in the rat. Toxicologist 10:224.
Daniel JW. 1978. Toxicity and metabolism of phthalate esters. Clin Toxicol 13:257–268.367696
Daniel JW. 1979. Toxicity and metabolism of phthalate esters. In: Winek L, Shanor SP, eds. Toxicology annual: Vol. 3. New York NY: Marcel Dekker, Inc., 257–268.
*Dannenberg E, Paquin L, Gwinnell H. 1992. Carbon (carbon black). In: Kroschwitz J, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons Inc., 1044–1045, 1072–1074.
David RM, Moore MR, Cifone MA, . 1999. Chronic peroxisome proliferation and hepatomegaly associated with the hepatocellular tumorigenesis of di(2-ethylhexyl)phthalate and the effects of recovery. Toxicol Sci 50:195–205.
*de Bruijn J, Busser F, Seinen W, . 1989. Determination of octanol/water partition coefficients for hydrophobic organic chemicals with the “slow-stirring” method. Environ Toxicol Chem 8:499–512.
DeFoe DL, Holcombe GW, Hammermeister DE, . 1990. Solubility and toxicity of eight phthalate esters to four aquatic organisms. Environ Toxicol Chem 9:623–636.
*DeLeon IR, Byrne CJ, Peuler EA, . 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15(6):795–805.
*Desideri P, Lepri L, Checchini L, . 1994. Organic compounds in surface and deep antarctic snow. Int J Environ Anal Chem 55:33–46.
Desideri PG, Lepri L, Udisti R, . 1998. Analysis of organic compounds in Antarctic snow and their origin. Int J Environ Anal Chem 71(3–4):331–351.
*DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
*Deyrup C. 1999. Chemical imports. Chemical Market Reporter 255(1):38–39.
Di Bella G, Saitta M, Pellegrino M, . 1999. Contamination of Italian citrus essential oils: Presence of phthalate esters. J Agric Food Chem 47:1009–1012.10552407
*Donovan S. 1996. New method for estimating vapor pressure by the use of gas chromatography. J Chromatogr A 749:123–129.
DOT. 1998. Department of Transportation. Code of Federal Regulations. Title 49, vol. 2, parts 100-185.
*DOT. 2001a. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Code of Federal Regulations 49 CFR 171.101, Appendix A. http://www.dot.gov. April 3, 2001.
*DOT. 2001b. List of marine pollutants. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 171.101. Appendix B. http://www.dot.gov. April 3, 2001.
*Eastman Chemical Company. 1999a. Kingsport, TN: Eastman Chemical Company, http://www.eastman.com/ProductCat/producthome.asp?Product=60&EastmanDotCom=True. August 5, 1999.
*Eastman Chemical Company. 1999b. Kingsport, TN: Eastman Chemical Company, http://www.eastman.com/ProductCat/ListApplications.asp?productid=60&EastmanDotCom=True. July 30, 1999.
Eaton RW, Ribbons DW. 1982. Metabolism of dibutyl phthalate and phthalate by Micrococcus sp. strain 12B. J Bacteriol 151:48–57.7085570
*Eckel W, Ross B, Isensee R. 1993. Pentobarbitol found in ground water. Ground Water 31(5):801–803.
Eckel W, Ross B, Isensee R. 1994. Reply to the preceding discussion by Douglas C. Bailey of “pentobarbitol found in ground water”. Ground Water 32:150–151.
*Edelman IS, Leibman J. 1959. Anatomy of body water and electrolytes. Am J Med 27:256–277.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Ekwall B, Nordensten C, Albanus L. 1982. Toxicity of 29 plasticizers to HeLa cells in the MIT-24 system. Toxicology 24:199–210.6927640
*Ellenhorn MJ, ed. 1997. Plastics, plasticizers, and epoxy resins. In: Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. Baltimore, Maryland: Williams & Wilkins, 1677–1680.
*Elsisi AE, Carter DE, Sipes IG. 1989. Dermal absorption of phthalate diesters in rats. Fundam Appl Toxicol 12:70–77.2925020
*Ema M, Amano H, Itami T, . 1993. Teratogenic evaluation of di-n-butyl phthalate in rats. Toxicol Lett 69:197–203.8212061
*Ema M, Amano H, Ogawa Y. 1994. Characterization of the developmental toxicity of di-n-butyl phthalate in rats. Toxicology 86:163–174.8128502
*Ema M, Harazono A, Miyawaki E, . 1997a. Developmental effects of di-n-butyl phthalate after a single administration in rats. J Appl Toxicol 17(4):223–229.9285534
*Ema M, Harazono A, Miyawaki E, . 1997b. Embryo lethality following maternal exposure to dibutyl phthalate during early pregnancy in rats. Bull Environ Contam Toxicol 58:636–643.9060383
*Ema M, Kurosaka R, Amano H, . 1995a. Comparative developmental toxicity of n-butyl benzyl phthalate and di-n-butyl phthalate in rats. Arch Environ Contam Toxicol 28:223–228.7710290
Ema M, Kurosaka R, Amano H, . 1995b. Developmental toxicity evaluation of mono-n-butyl phthalate in rats. Toxicol Lett 78:101–106.7618175
*Ema M, Kurosaka R, Harazono A, . 1996. Phase specificity of developmental toxicity after oral administration of mono-n-butyl phthalate in rats. Arch Environ Contam Toxicol 31:170–176.8781065
*Ema M, Miyawaki E, Kawashima K. 1998. Further evaluation of developmental toxicity of di-n-butyl phthalate following administration during late pregnancy in rats. Toxicol Lett 98:87–93.9776565
*Ema M, Miyawaki E, Kawashima K. 2000a. Critical period for adverse effects on development of reproductive system in male offspring of rats given di-n-butyl phthalate during late pregnancy. Toxicol Lett 111:271–278.10643872
*Ema M, Miyawaki E, Kawashima K. 2000b. Effects of dibutyl phthalate on reproductive function in pregnant and pseudopregnant rats. Reprod Toxicol 14:13–19.10689199
EMMI. 1999. EPA environmental monitoring methods index: Detail analyte. Version I. PC no. 4082. Rockland, MD: Government Institutes.
Engelhardt G, Wallnofer PR. 1978. Metabolism of di- and mono-n-butyl phthalate by soil bacteria. Appl Environ Microbiol 35:243–246.16345266
Engelhardt G, Wallnöfer PR, Hutzinger O. 1975. The microbial metabolism of di- n-butyl phthalate and related dialkyl phthalates. Bull Environ Contam Toxicol 13(3):342–347.1125463
EPA. 1979. Water-related environmental fate of 129 priority pollutants: Volume I: Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA-440/4-79-029a. NTIS No. PB 80-204373.
EPA. 1980a. U.S. Environmental Protection Agency. Federal Register. 45:33084–33133.
*EPA. 1980b. Ambient water quality criteria for: Phthalate esters. Washington, DC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA-440/5-80-067. NTIS No. PB81-117780.
*EPA. 1981. An exposure and risk assessment for phthalate esters: Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA-440/4-81-020. NTIS No. PB85-211936.
EPA. 1982a. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/4-81-014.
EPA. 1982b. Test method: Phthalate esters-method 606. In: Longbottom JE, Lichtenberg JJ, eds. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4-82-057.
EPA. 1982c. Test method: Base/neutrals and acids-method 625. In: Longbottom JE, Lichtenberg JJ, eds. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4-82-057.
EPA. 1982d. U.S. Environmental Protection Agency. Federal Register. 47:26992–27008.
EPA. 1983a. Reportable quantity document for 1,2-benzene dicarboxylic acid, dibutyl ester (dibutyl phthalate). Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. External Review Draft. ECAO-CIN-R039.
EPA. 1983b. Treatability manual: Volume I. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2-82-001a.
*EPA. 1984a. Development of a fate/toxicity screening test. Gulf Breeze, FL: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/4-84-074. NTIS No. PB84-246370.
*EPA. 1984b. U.S. Environmental Protection Agency. Federal Register. 49:209.
EPA. 1984c. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates: Volume I: Analysis results for 17 drinking water, 16 advanced waste treatment and 3 process blank concentrates. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/1-84-020a. NTIS No. PB85-128221.
EPA. 1985. U.S. Environmental Protection Agency: Part II. Federal Register 50:13456–13522.
*EPA. 1986a. Method 8060: Phthalate esters. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Method 8250: Gas chromatography/mass spectrometry for semivolatile organics: Packed column technique. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. Method 8270: Gas chromatography/mass spectrometry for semivolatile organics: capillary column technique. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986d. Method 8410: Capillary column analysis of semivolatile organic compounds by gas chromatography/fourier transform infrared (GC/FT-IR) spectrometry. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986e. Method 8060: Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique. In: Test methods for evaluating solid waste. 3^rd^ ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986f. Toxic and priority organics in municipal sludge land treatment systems. Cincinnati OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/2-86/010. NTIS No. PB86-150208.
*EPA. 1986g. Broad scan analysis of the FY82 national human adipose tissue survey specimens: Volume I-Executive summary. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA 560/5-86-035.
EPA. 1987a. U.S. Environmental Protection Agency: Part II. Federal Register. 52:13378–13410.
EPA. 1987b. U.S. Environmental Protection Agency: Part II. Federal Register. 52:25942–25953.
*EPA. 1987c. Health effects assessment for selected phthalic acid esters. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA/600/8-88/053. NTIS No. PB88-178934.
EPA. 1987d. U.S. Environmental Protection Agency. Federal Register. 52:48073–48074.
EPA. 1987e. Reference dose (RfD): Description and use in health risk assessments. Volume I, Appendix A: Integrated Risk Information System supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-86/032a.
EPA. 1988a. U.S. Environmental Protection Agency: Part II. Federal Register. 53:31138–31222.
EPA. 1988b. U.S. Environmental Protection Agency: Part II. Federal Register. 53:4500–4539.
EPA. 1988c. U.S. Environmental Protection Agency: Part V. Federal Register. 53:38642–38654.
EPA. 1989a. Interim Methods for Development of Inhalation References Doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88/066F.
EPA. 1989b. U.S. Environmental Protection Agency: Part II. Federal Register. 54:1056–1120.
EPA. 1989c. U.S. Environmental Protection Agency. Federal Register. 54:618–621.
*EPA. 1989d. Hydrolysis rate constants for enhancing property-reactivity relationships. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. PB 89-220479.
*EPA. 1990a. Characterization of municipal waste combustion ash, ash extracts, and leachates. Washington, DC: U.S. Environmental Protection Agency. EPA530-SW-90-029A.
*EPA. 1990b. Interim methods for the development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-90/066A.
*EPA. 1992. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR260-299.
*EPA. 1993. Reference guide to odor thresholds for hazardous air pollutants listed in the clean air act amendments of 1990. Washington, DC: U.S. Environmental Protection Agency. PB92-239516.
*EPA. 1994a. Method 8250A: Semivolatile organic compounds by gas chromatography/mass spectrometry (GS/MS). Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1994b. Method 8410: Gas chromatography/fourier transform infrared (GC/FT-IR) spectrometry for semivolatile organics: Capillary column. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1996a. Drinking Water Regulations and Health Advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-B-96-002.
*EPA. 1996b. Method 8061A: Phthalate esters by gas chromatography with electron capture detection (GC/ECD). Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. EPA/630/R-96/012.
EPA. 1998a U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1998b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.
EPA. 1998c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1998d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.
EPA. 1998e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1998f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 467.2.
EPA. 1998g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 465.02.
EPA. 1998h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
EPA. 1998i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
EPA. 1998j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 469.12.
EPA. 1998k. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.101.
EPA. 1998l. U.S. Method 8270: Semivolatile organic compounds by gas chromatography/mass spectrometry (GS/MS). Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1999a. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs http://www.epa.gov/opprd001/inerts/list2inerts.html. August 5, 1999.
*EPA. 1999b. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs http://www.epa.gov/opppmsd1/DataSubmittersList/dslchem.htm. August 5, 1999.
*EPA. 1999c. National recommended water quality criteria-correction. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
EPA. 1999d. Toxic chemical release reporting: Community right-to-know: Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_99/40cfr372_99.html. February 8, 2001.
*EPA. 1999e. Identification of specific chemical substance and mixture testing requirements: Testing consent orders for substances and mixtures with chemical abstract service registry numbers. U.S. Environmental Protection Agency. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_99/40cfr799_99.html. February 8, 2001.
EPA. 2000a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfr14_00.html. October 25, 2000.
EPA. 2000b. Identification and listing of hazardous waste: Discarded commercial chemical products, off-specification species, container residues and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfr261_00.html. February 8, 2001.
EPA. 2000c. National drinking water contaminant occurrence database. Envirofacts Warehouse. U.S. Environmental Protection Agency. http://www.epa.gov:9966.
*EPA. 2001a. Applicability: description of the bulk organic chemicals subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.70, Appendix C. http://www.access.gpo.gov/nara/cfr/...1_00/Title_40/40cfr414_main_00.html. April 3, 2001.
*EPA. 2001b. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.access.gpo.gov/nara/cfr/...100/Title_40/40cfr372main_00.html. April 5, 2001.
*EPA. 2001c. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.access.gpo.gov/nara/cfr/...100/Title_40/40cfr116_main_00.html. April 5, 2001.
*EPA. 2001d. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr302main00.html. April 5, 2001.
*EPA. 2001e. Di-n-butyl phthalate: 84-74-2. U.S. Environmental Protection Agency. Office of Air Quality Planning and Standards. http://www.epa.gov/ttnuatwl/hlthef/di-n-but.html. January 8, 2001.
*EPA. 2001f. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr261main00.html. April 5, 2001.
*EPA. 2001g. General definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr465main00.html. April 5, 2001.
*EPA. 2001h. General definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 467.02. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr467main00.html. April 5, 2001.
*EPA. 2001i. General definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://www.accessgpo.gov/nara/cfr/...100/Title40/40cfr264main00.html. April 5, 2001.
*EPA. 2001j. List of hazardous inorganic and organic constituents 1. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, Appendix II. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr258main00.html. April 3, 2001.
*EPA. 2001k. Listed constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Appendix I. http://www.access.gpo/gov/nara/cfr/...1_00/Title_40/40cfr192_main_00.html. April 3, 2001.
EPA. 2001l. NPDES permit testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.21, Appendix D. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr122main00.html. April 3, 2001.
EPA. 2001m. NPDES permit testing requirements for publicly owned treatment works. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.21, Appendix J. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr403main00.html. April 3, 2001.
*EPA. 2001n. Pollutants eligible for a removal credit. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403, Appendix G. http://www.access.gpo/nara/cfr/...100/Title4/40cfr403main00.html. April 3, 2001.
*EPA. 2001o. Priority pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423, Appendix A. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr266main00.html. April 4, 2001.
*EPA. 2001p. Reference air concentrations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix IV. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr266main00.html. April 3, 2001.
*EPA. 2001q. Specialized definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr433.11main00.html. April 3, 2001.
*EPA. 2001r. Substances and listed mixtures with chemical abstract service registry numbers. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr716.120main00.html. April 5, 2001.
*EPA. 2001s. Testing consent orders for substances and mixtures with chemical abstract service registry numbers. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 799.5000. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr799.5000main00.html. April 5, 2001.
*EPA. 2001t. Toxic criteria for those states not complying with Clean Water Act section 303(c)(2)(B). U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 131.36. http://www.access.gpo.gov/nara/cfr/..100/Title40/40cfr131.36main00.html. April 3, 2001.
*EPA. 2001u. Toxic pollutants effluent limitations and standards for direct discharge point sources that use end-of-pipe biological treatment. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.91. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr414.91main00.html. April 3, 2001.
*EPA. 2001v. Toxic pollutant effluent limitations and standards for direct discharge point sources that do not use end-of-pipe biological treatment. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.101. http://www.access.gpo.gov/nara/cfr/..100/Title40/40cfr414.101main00.html. April 3, 2001.
*EPA. 2001w. Toxic pollutant standards for indirect discharge point sources. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.111. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr414.111main00.html. April 3, 2001.
*EPA. 2001x. Universal treatment standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48. http://www.access.gpo.gov/nara/cfr/...100/Title40/40cfr268.48main00.html. April 3, 2001.
*Fallon ME, Horvath FJ. 1985. Preliminary assessment of contaminants in soft sediments of the Detroit River. J Great Lakes Res 11(3):373–378.
FDA. 1998a. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.2600.
FDA. 1998b. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1200.
FDA. 1998c. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
FDA. 1998d. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.170.
*FDA. 1999. Indirect food additives: Paper and paperboard components: Components of paper and paperboard in contact with aqueous and fatty foods. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.170. http://www.access.gpo.gov/nara/cfr/waisidx_99/21cfr176_99.html. February 2, 2001.
*FDA. 2000a. Indirect food additives: Adhesives and components of coatings: Adhesives. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr175_00.html. February 2, 2001.
*FDA. 2000b. Indirect food additives: Polymers: Cellophane. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1200. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr177_00.html. February 2, 2001.
*FDA. 2000c. Indirect food additives: Polymers: Substances for use only as components of articles intended for repeated use: Rubber articles intended for repeated use. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.2600. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr177_00.html. February 2, 2001.
*FDA. 2000d. Components of paper and paperboard in contact with aqueous and fatty food. National Archives and Records Administration. Code of Federal Regulations. 21 CFR 176.170. http://www.access.gpo.gov/nara/cfr/waisidx00/21cfr176.00.html. April 5, 2001.
*FDA. 2000e. Polyester resins, cross-linked. National Archives and Records Administration. Code of Federal Regulations. 21 CFR 177.2420, Appendix B. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr175_00.html. April 3, 2001.
*FDA. 2000f. Resinous and polymeric coatings. National Archives and Records Administration. Code of Federal Regulations. 21 CFR 175.300. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr175_00.html. April 3, 2001.
*FDA. 2000g. Slimicides. National Archives and Records Administration. Code of Federal Regulations 21 CFR 176.300, Appendix D. http://www.access.gpo.gov/nara/cfr/waisidx00/21cfr17600.html. April 3, 2001.
*FEDRIP. 1999. Federal Research in Progress: di-n-butyl Phthalate. Dialog Information Services, Inc. Palo Alto, CA. February 1992.
*FEDRIP. 2000. Federal Research in Progress: di-n-butyl Phthalate. Dialog Information Services, Inc. Palo Alto, CA.
*Feiler HD, Storch PJ, Southworth R. 1980. Organics in municipal sludges survey of forty cities. Natl Conf Munic Ind Sludge Util Disposal [pap.], 53–57.
*Felthouse TR, Burnett JC, Mitchell SF, . 1995. Maleic anhydride, maleic and fumaric acid. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 902–928.
*Ferrario JB, DeLeon IR, Tracy RE. 1985. Evidence for toxic anthropogenic chemicals in human thrombogenic coronary plaques. Arch Environ Contam Toxicol 14:529–534.4051565
Fishbein L. 1984. Toxicity of the components of styrene polymers: Polystyrene, acrylonitrile-butadiene-styrene (ABS) and styrene-butadiene-rubber (SBR). Reactants and additives. In: Jarvisalo J, Pfaffli P, Vainio H, eds. Industrial hazards of plastics and synthetic elastomers. New York NY: Alan R. Liss, Inc., 239–262.
*Fishbein L. 1992. Exposure from occupational versus other sources. Scand J Work Environ Health 18(suppl 1):5–16.
*Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ test. Toxicology 18:219–232.
*Fomon SJ. 1966. Body composition of the infant. Part I: The male “reference infant”. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Foster PM, Cook MW, Thomas LV, . 1982. Differences in urinary metabolic profile from di-n-butyl phthalate-treated rats and hamsters: A possible explanation for species differences in susceptibility to testicular atrophy. Drug Metab Dispos 11(1):59–61.
Foster PM, Lake BG, Cook MW, . 1981. Structure-activity requirements for the induction of testicular atrophy by butyl phthalates in immature rats: Effect on testicular zinc content. In: Snyder R, Parke DV, Kocsis JJ, . eds. Biological reactive intermediates-II: Chemical mechanisms and biological effects Part A. New York, NY: Plenum Press, 445–452.
Foster PM, Thomas LV, Cook MW, . 1980. Study of the testicular effects and changes in zinc excretion produced by some n-alkyl phthalates in the rat. Toxicol Appl Pharmacol 54:392–398.7394794
*Fricker C, Hardy J. 1990. Characterization of commercially available coffee filter papers. J Environ Sci Health Part A 25(8):927–936.
FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee.
*Fukuoka M, Kobayashi T, Hayakawa T. 1994. Mechanism of testicular atrophy induced by di-n-butyl phthalate in rats. VI. A possible origin of testicular iron depletion. Biol Pharm Bull 17(12):1609–1612.7735204
*Fukuoka M, Kobayashi T, Hayakawa T. 1995. Mechanism of testicular atrophy induced by di-n-butyl phthalate in rats. Part 5. Testicular iron depletion and levels of ferritin, hemoglobin and transferrin in the bone marrow, liver and spleen. J Appl Toxicol 15(5):379–386.8666721
*Fukuoka M, Kobayashi T, Zhou Y, . 1993. Mechanism of testicular atrophy induced by di-n-butyl phthalate in rats. Part 4. Changes in the activity of succinate dehydrogenase and the levels of transferring and ferritin in the sertoli and germ cells. J Appl Toxicol 13(4):241–246.8376724
*Fukuoka M, Tanimoto T, Zhou Y, . 1989. Mechanism of testicular atrophy induced by di-n- butyl phthalate in rats. Part 1. J Appl Toxicol 9(4):277–283.2506265
*Fukuoka M, Zhou Y, Tanaka A, . 1990. Mechanism of testicular atrophy induced by di-n-butyl phthalate in rats. Part 2. The effects on some testicular enzymes. J Appl Toxicol 10(4):285–293.2391408
Gangolli SD. 1982. Testicular effects of phthalate esters. Environ Health Perspect 45:77–84.6754364
Geissert JO. 1977. Technical assistance report no. TA-76-66. Cincinnati, OH: National Institute for Occupational Safety and Health. NTIS No. PB82-189747.
*Germain A, Langlois C. 1988. Contamination des eaux et des sediments en suspension du fleuve saint-laurent par les pesticides organochlores, les biphenyles polychlores et d’autres contaminants organiques prioritaires. Water Pollut Res J Can 23(4):602–614.
Gesler RM. 1973. Toxicology of di-2-ethylhexyl phthalate and other phthalic-acid ester plasticizers. Environ Health Perspect 3:73–79.4574364
*Giam CS, Wong MK. 1987. Plasticizers in food. J Food Prot 50(9):769–782.30978802
*Giam CS, Atlas E, Chan HS, . 1980. Phthalate esters, PCB and DDT residues in the Gulf of Mexico atmosphere. Atmos Environ 14:65–69.
Giam CS, Chan HS, Neff GS. 1978a. Phthalate ester plasticizers, DDT, DDE and polychlorinated biphenyls in biota from the Gulf of Mexico. Mar Pollut Bull 9:249–251.
Giam CS, Chan HS, Neff GS, . 1978b. Phthalate ester plasticizers: A new class of marine pollutant. Science 199:419–421.413194
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goncharuk EI, Sidorenko GI, Golubchikov MV. 1990. [Use of the mother-fetus-newborn infant system of combined effects of pesticides and other chemicals]. Gig Sanit Jun(6):4–7. (Russian)
Gosselin RE, Smith RP, Hodge HC, . eds. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore MD: Williams and Wilkins, II–204.
Gothe R. 1974. Oxidation with tetrabutylammonium permanganate for quantitation of DDT residues in GLC determination of chlorinated hydrocarbons. Bull Environ Contam Toxicol 11:451–455.4433831
Gray LE, Ostby JS, Mylchreest E, . 1998. Dibutyl phthalate (DBP) induces antiandrogenic but not estrogenic in vivo effects in LE Hooded rats. Toxicologist 42(1-S):176.
Gray LE, Ostby J, Sigmon R J, . 1988. The development of a protocol to assess reproductive effects of toxicants in the rat. Reprod Toxicol 2:281–287.2485184
*Gray LE, Wolf C, Lambright C, . 1999. Administration of potentially antiandrogenic pesticides (procymidone, linuron, iprodione, chlozolinate, p,p′-DDE, and ketoconazole) and toxic substances (dibutyl- and diethylhexyl phthalate, PCB 169, and ethane dimethane sulphonate) during sexual differentiation produces diverse profiles of reproductive malformations in the male rat. Toxicol Ind Health 15(1–2):94–118.10188194
*Gray TJ, Gangolli SD. 1986. Aspects of the testicular toxicity of phthalate esters. Environ Health Perspect 65:229–235.3709446
*Gray TJ, Rowland IR, Foster PM, . 1982. Species differences in the testicular toxicity of phthalate esters. Toxicol Lett 11:141–147.7090005
Green DR, Le Pape D. 1987. Stability of hydrocarbon samples on solid-phase extraction columns. Anal Chem 59:699–703.
*Grollert C, Kasper A, Puxbaum H. 1997. Organic compounds in high alpine snow. Int J Environ Anal Chem 67:213–222.
Gulati DK, Hope E, Teague J, . 1991. Reproductive toxicity assessment by continuous breeding in Sprague-Dawley rats: A comparison of two study designs. Fundam Appl Toxicol 17:270–279.1765220
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and Differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haley TJ. 1975. Vinyl chloride: How many unknown problems? J Toxicol Environ Health 1:47–73.1102724
Hall DE, Austin P, Fairweather FA. 1966. Acute (mouse and rat) and short-term (rat) toxicity studies on dibutyl(diethylene glycol bisphthalate). Food Cosmet Toxicol 4:383–388.5975244
*Hannah SA, Austern BM, Eralp AE, . 1986. Comparative removal of toxic pollutants by six wastewater treatment processes. J Water Pollut Control Fed 58(1):27–34.
Hannah SA, Austern BM, Eralp AE, . 1988. Removal of organic toxic pollutants by trickling filter and activated sludge. J Water Pollut Control Fed 60:1281–1283.
*Hansch C, Leo A, Hoekman D, eds. 1995. Exploring QSAR; Hydrophobic electronic, and steric constants. Washington, DC: American Chemical Society, 144.
*Hardin BD. 1987. A recommended protocol for the Chernoff/Kavlock preliminary developmental toxicity test and a proposed method for assigning priority scores based on results of that test. Teratog Carcinog Mutagen 7:85–94.2884747
*Hardin BD, Schuler RL, Burg JR, . 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratog Carcinog Mutagen 7:29–48.2884741
*Harris CA, Henttu P, Parker MG, . 1997. The estrogenic activity of phthalate esters in vitro. Environ Health Perspect 105(8):802–811.9347895
Harsanyi BB, Foong WC, Jones DW. 1988. Implantation of denture soft polymers into hamster cheek pouch [Abstract]. J Dent Res 67:263.
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
Hawker DW, Connell DW. 1986. Bioconcentration of lipophilic compounds by some aquatic organisms. Ecotoxicol Environ Saf 11:184–197.3709407
Hawthorne SB. 1988. 1988 workshop on supercritical fluid chromatography. American Laboratory (August 1988):6–8.
*HazDat. 1999. Agency for Toxic Substances and Disease Registry(ATSDR). Results of HazDat searches for group 13 chemicals. Atlanta, GA.
*HazDat. 2001. Agency for Toxic Substances and Disease Registry(ATSDR). Results of HazDat searches for group 13 chemicals. Atlanta, GA.
*Hazleton Biotechnologies. 1986. Mutagenicity of IC in a mouse lymphoma mutation assay: Final report. Hazleton Biotechnologies Company, Kensington, MD. HB Project No. 20989.
*Heitkamp MA, Johnson B. 1984. Impact of an oil field effluent on microbial activities in a Wyoming river. Can J Microbiol 30:786–792.6488102
*Ho C-T, Lee KN, Jin QZ. 1983. Isolation and identification of volatile flavor compounds in fried bacon. J Agric Food Chem 31:336–342.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J. Natl Cancer Inst 84(5):313–320.1738181
*Hoff RM, Chan K-W. 1987. Measurement of polycyclic aromatic hydrocarbons in the air along the Niagara River. Environ Sci Technol 21:556–561.19994975
Horton R. 2000. Retraction: Interferon alfa-2b... in Behçet’s disease. Lancet 356:1292–1299.
*Howard PH, ed. 1989. Handbook of environmental fate and exposure data of environmental chemicals. Vol. 1. Large production and priority pollutants. Chelsea, MA: Lewis Publishing Inc., 217–228.
Howard PH, Banerjee S, Robillard KH. 1985. Measurement of water solubilities, octanol/water partition coefficients and vapor pressures of commercial phthalate esters. Environ Toxicol Chem 4:653–661.
Howarth JA, Price SC, Dobrota M, . 2001. Effects on male rats of di-(2-ethylhexyl) phthalate and di-n-hexylphthalate administered alone or in combination. Toxicol Lett 121:35–43.11312035
HSDB. 1988. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 1988.
HSDB. 1999. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. May 17, 1999.
HSDB. 2000. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 2000.
*HSDB. 2001. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. February 2001.
Hudson RA, Austerberry CF, Bagshaw JC. 1981. Phthalate ester hydrolases and phthalate ester toxicity in synchronously developing larvae of the brine shrimp (Artemia). Life Sci 29:1865–1872.7311720
Hudson VW. 1982. TSCA interagency testing committee actions related to phthalates. Environ Health Perspect 45:135–136.7140686
Husain SL. 1975. Dibutyl phthalate sensitivity. Contact Dermatitis 1:395.
Hutchins SR, Tomson MB, Ward CH. 1983. Trace organic contamination of ground water from a rapid infiltration site: A laboratory-field coordinated study. Environ Toxicol Chem 2:195–216.
Imajima T, Shono T, Zakari O, . 1997. Prenatal phthalate causes crytorchidism postnatally by inducing transabdominal ascent of testis in fetal rats. J Pediatr Surg 32(1):18–21.9021559
*Inman JC, Strachan SD, Sommers LE, . 1984. The decomposition of phthalate esters in soil. J Environ Sci Health B19(2):245–257.
*Inouye B, Ogino Y, Ishida T, . 1978. Effects of phthalate esters on mitochondrial oxidative phosphorylation in the rat. Toxicol Appl Pharmacol 43:189–198.24285
IRIS. 1999. Dibutyl phthalate. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov./IRIS/subst/0038.htm. April 19, 1999.
*IRIS. 2001. Dibutyl phthalate. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov./IRIS/subst/0038.htm. January 8, 2001.
*IRDC. 1984. Study of fertility and general reproductive performance in rats (IR-83-145). International Research and Development Corporation: Mattawan, MI.
IRPTC. 1989. IRPTC data profile on: Dibutyl phthalate. International Register of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva, Switzerland. January 1989.
*Ishida M, Suyama K, Adachi S. 1981. Occurrence of dibutyl and di(2-ethylhexyl) phthalate in chicken eggs. J Agric Food Chem 29:72–74.7193699
*Ishidate M Jr, Odashima S. 1977. Chromosome tests with 134 compounds on Chinese hamster cells in vitro—a screening for chemical carcinogens. Mutat Res 48:337–353.876270
Jansson B, Jensen S, Olsson M, . 1975. Identification by GC-MS of phenolic metabolites of PCB and p,p′-DDE isolated from Baltic guillemot and seal. Ambio 4:93–97.
*Jay K, Steiglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30(7):1249–1260
Jianlong W, Lujun C, Hanchang S, . 2000. Microbial degradation of phthalic acid esters under anaerobic digestion of sludge. Chemosphere 41:1245–1248.10901254
Jianlong W, Ping L, Hanchang S, . 1997. Biodegradation of phthalic acid ester in soil by indigenous and introduced microorganisms. Chemosphere 35(8):1747–1754.
*Jobling S, Reynolds T, White R, . 1995. A variety of environmentally persistent chemicals, including some phthalate plasticizers, are weakly estrogenic. Environ Health Perspect 103(6):582–587.7556011
*Johanson CE. 1980. Permeability and vascularity of the developing brain: cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
John JA, Wroblewski DJ, Schwetz BA. 1984. Teratogenicity of experimental and occupational exposure to industrial chemicals. Issues Rev Terat 2:267–324.
*Johnson BT, Lulves W. 1975. Biodegradation of di-n-butyl phthalate and di-2-ethylhexyl phthalate in fresh water hydrosoil. J Fisher Res Board Can 32(3):333–339.
*Johnson BT, Heitkamp MA, Jones JR. 1984. Environmental and chemical factors influencing the biodegradation of phthalic acid esters in freshwater sediments. Environ Pollut (Series B) 8:101–118.
Johnson BT, Stalling DL, Hogan JW, . 1977. Dynamics of phthalic acid esters in aquatic organisms. In: Suffet IH, ed. Fate of pollutants in the air and water environments: Part 2. Chemical and biological fate of pollutants in the environment. New York, NY: John Wiley and Sons, 283–300.
Johnson EM, Gabel BE. 1983. An artificial embryo for detection of abnormal developmental biology. Fundam Appl Toxicol 3:243–249.6628885
Johnson EM, Newman LM, Gabel BE, . 1988. An analysis of the Hydra assay’s applicability and reliability as a developmental toxicity prescreen. J Am Coll Toxicol 7:111–126.
Jones AE, Kahn RH, Groves JT, . 1975. Phthalate ester toxicity in human cell cultures. Toxicol Appl Pharmacol 31:283–289.1129799
*Jones D, Burklin C, Seaman J. 1996. Models to estimate volatile organic hazardous air pollutant emissions from municipal sewer systems. J Air Waste Manag Assoc 46:657–666.28081393
Jury WA, Winer AM, Spencer WF, . 1987. Transport and transformations of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:119–164.
Kamiya A, Ose Y. 1987. Mutagenic activity and PAH analysis in municipal incinerators. Sci Total Environ 61:37–49.
Kaneshima H, Yamaguchi T, Itoh K. 1978a. Studies on the effects of phthalate esters on the biological system: (Part 3). The in vitro metabolism of dibutyl phthalate in the small intestines of rats. Bull Environ Contam Toxicol 20:725–728.749972
*Keys DA, Wallace DG, Kepler TB, . 1999. Quantitative evaluation of alternative mechanisms of blood and testes disposition of di(2-ethylhexyl0 phthalate and mono(2-ethylhexyl) phthalate in rats. Toxicol Sci 49:172–185.10416263
Kaneshima H, Yamaguchi T, Okui T, . 1978b. Studies on the effects of phthalate esters on the biological system (Part 2) In vitro metabolism and biliary excretion of phthalate esters in rats. Bull Environ Contam Toxicol 19:502–509.656651
*Kaplan W, ed. 1998. Trade names and designations of plasticizers. Modern Plastics Encyclopedia 1999. 75(12):c111, c115.
Kawamura K, Kaplan IR. 1983. Organic compounds in the rainwater of Los Angeles. Environ Sci Technol 17:497–501.22283170
*Kawano M. 1980a. [Toxicological studies on phthalate esters. 1. Inhalation effects of dibutyl phthalate (DBP) on rats.] Nippon Eiseigaku Zasshi (Jpn J Hyg) 35:684–692. (Japanese).
*Kawano M. 1980b. [Toxicological studies on phthalate esters. 2. Metabolism, accumulation and excretion of phthalate esters in rats.] Nippon Eiseigaku Zasshi (Jpn J Hyg) 35:693–701. (Japanese)
*Kawashima Y, Hanioka N, Matsumura M, . 1983. Induction of microsomal stearoyl-CoA desaturation by the administration of various peroxisome proliferators. Biochim Biophys Acta 752:259–264.6134555
*Keith LH, Garrison AW, Allen FR, . 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 329–362.
Kerster HW, Schaeffer DJ. 1983. Brine shrimp (Artemia salina) Nauplii as a teratogen test system. Ecotoxicol Environ Saf 7:342–349.6872918
*Keys DA, Wallace DG, Kepler TB, . 2000. Quantitative evaluation of alternative mechanisms of blood disposition of di(n-butyl) phthalate and mono(n-butyl) phthalate in rats. Toxicol Sci 53:173–184.10696765
Killinger JM, Basaran AH, Mezza LE, . 1988a. Prechronic dosed feed study of dibutyl phthalate (CAS No. 84-74-2) in B6C3F, mice (phase I - maximum perinatal dose). Report to National Toxicology Program, Research Triangle Park, NC, by Battelle, Columbus, OH.
Killinger J, Basaran A, Mezza L, . 1989. Perinatal dose study of dibutyl phthalate in rats and mice. Toxicologist 9(1):273.
Killinger LM, Basaran AH, Persing RL, . 1988b. Maximum perinatal dose feed study of dibutyl phthalate (CAS No. 84-74-2) in Fischer 344 rats. Research Triangle Park: National Toxicology Program.
Killinger JM, Melnick R, Basaran A, . 1991. Effect of dibutyl phthalate on the F344 rat with and without in utero exposure. Toxicologist 11:341.
*Kinman R, Nutini D, Carson D. 1995. Evaluation of leachate and gas from sanitary landfills with and without HHW components. Proc Ind Waste Conf 49:263–269.
*Kleisasser NH, Kastenbauer ER, Weissacher H, . 2000. Phthalates demonstrate genotoxicity on human mucosa of the upper aerodigestive tract. Environ Mol Mutagen 35:9–12.
Kluwe WM. 1982. Overview of phthalate ester pharmacokinetics in mammalian species. Environ Health Perspect 45:3–9.6754362
Knudsen FR, Pottinger TG. 1999. Interaction of endocrine disrupting chemicals, singly and in combination, with estrogen-, androgen-, and corticosteroid-binding sites in rainbow trout (oncorhynchus mykiss). Aquat Toxicol 44:159–170.
*Kodama T, Takai Y. 1974. [Determination of phthalate esters.] Kogai lo saroaku 10:977–980. (Japanese).
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kool HJ, van Kreijl CF, Zoeteman BC. 1982. Toxicology assessment of organic compounds in drinking water. CRC Crit Rev Environ Control 12:307–357.
Korhonen A, Hemminki K, Vainio H. 1983. Embryotoxic effects of phthalic acid derivatives, phosphates and aromatic oils used in the manufacturing of rubber on 3 day chicken embryos. Drug Chem Toxicol 6:191–208.6872883
*Krauskopf LG. 1973. Studies of the toxicity of phthalates via ingestion. Environ Health Perspect 3:61–72.4735798
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology 3^rd^ ed. New York, NY: Academic Press, 399–437.
*Krishnan K, Andersen ME, Clewell H 3rd, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York, NY: Raven Press, 149–188.
Kurane R. 1986. Microbial degradation of phthalate esters. Microbiol Sci 3:92–95.3153148
Kurane R, Suzuki T, Takahara Y. 1979. Microbial population and identification of phthalate esterutilizing microorganisms. Agric Biol Chem 43:907–917.
Lake BG, Cook WM, Worrell NR, . 1991. Dose-response relationships for induction of hepatic peroxisome proliferation and testicular atrophy by phthalate esters in the rat [Abstract]. Hum Exp Toxicol 10:67–68.
*Lake BG, Phillips JC, Linnell JC, . 1977. The in vitro hydrolysis of some phthalate deters by hepatic and intestinal preparations from various species. Toxicol Appl Pharmacol 39:239–248.403636
*Lamb JC, Chapin RE, Teague J, . 1987. Reproductive effects of four phthalic acid esters in the mouse. Toxicol Appl Pharmacol 88:255–269.3564043
Lamb JC, Reel J, Lawton AD, . 1997. Di-n-butyl phthalate, mice. Environ Health Perspect Suppl 105:247–248.
Lao RC, Oja H, Thomas RS, . 1973. Assessment of environmental problems using the combination of gas chromatography and quadruple mass spectrometry. Sci Total Environ 2:223–233.4804496
Lawrence WH, Malik M, Turner JE, . 1975. A toxicological investigation of some acute, short-term, and chronic effects of administering di-2-ethylhexyl phthalate (DEHP) and other phthalate esters. Environ Res 9:1–11.1122902
Layton DW, Mallon BJ, Rosenblatt DH, . 1987. Deriving allowable daily intakes for systemic toxicants lacking chronic toxicity data. Regul Toxicol Pharmacol 7:96–112.3575800
Layton DW, McKone TE, Hall CH, . 1986. Demilitarization of conventional ordinance: Priorities for data-base assessments of environmental contaminants. Fort Detrick, Federick, MD: U.S. Army Medical Research and Development Command. ADA 182922.
*LBI. 1985a. Evaluation of 1C in the in vitro transformation of BALB/3T3 cells assay: Final Report. Litton Bionetics, Inc. Chemical Manufacturers Association, Washington, DC. LBI Project No. 20992.
LBI. 1985b. Evaluation of IC in the mouse lymphoma toxicity assay: Final report. Litton Bionetics, Inc. Chemical Manufacturers Association, Washington, DC. LBI Project No. 20989.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
LeFaux R, ed. 1968. Practical toxicology of plastics. Cleveland, OH: The Chemical Rubber Co., 137–138, 346–349, 412–419.
*Lehman AJ. 1955. Insect repellents. Assoc of Food and Drug Officials. Quarterly Bulletin 19:87–99.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. New York NY: Stockton Press, 153–164.
*Lewis R. 1993. Dibutylphenyl phosphate. In: Lewis R, ed. Hawley’s condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company, 374.
Ligocki MP, Pankow JF. 1985. Assessment of absorption/solvent extraction with polyurethane foam and adsorption/thermal desorption with Tenax-GC for the collection and analysis of ambient organic vapors. Anal Chem 57:1138–1144.
Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain-II. Gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
Lindner V. 1991a. Explosives and propellants (explosives). In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 21, 56.
Lindner V. 1991b. Explosives and propellants (propellants). In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 69, 115.
*Lindner V. 1993a. Explosives and propellants (explosives). In: Kroschwitz J, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology 4^th^ ed. New York NY: John Wiley & Sons, Inc., 21, 56–68.
*Lindner V. 1993b. Explosives and propellants (propellants). In: Krowschwitz J, Howe-Grant, eds. Kirk-Othmer encyclopedia of chemical technology 4^th^ ed. New York NY: John Wiley & Sons Inc., 69, 115–125.
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lock EA, Mitchell AM, Elcombe CR. 1989. Biochemical mechanisms of induction of hepatic peroxisome proliferation. Ann Rev Pharmacol Toxicol 29:145–163.2658768
*Lygre H, Solheim E, Gjerdet N, . 1993. Leaching of organic additives from dentures in vivo. Acta Odontol Scand 51:45–51.8451923
*Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods; Environmental behavior of organic compounds. New York NY: McGraw-Hill Book Co., 4–1 - 4–3.
*MAFF. 1995. Food surveillance information sheet. MAFF-UK - Phthalates in paper and board packaging. Ministry of Agriculture, Fisheries, and Food. http://www.foodstandards.gov.uk/maff. October 16, 2000.
*MAFF. 1996a. Food surveillance information sheet. MAFF-UK - Phthalates in food. Ministry of Agriculture, Fisheries, and Food. http://www.foodstandards.gov.uk/maff. October 16, 2000.
*MAFF. 1996b. Food surveillance information sheet. MAFF-UK - Phthalates in infant formula. Ministry of Agriculture, Fisheries, and Food. http://www.foodstandards.gov.uk/maff.. October 16, 2000.
*MAFF. 1998. Food surveillance information sheet. MAFF-UK - Phthalates in infant formula - follow-up survey. Ministry of Agriculture, Fisheries, and Food. http://www.foodstandards.gov.uk/maff. October 16, 2000.
*Matsuda K, Schnitzer M. 1971. Reactions between fulvic acid, a soil humic material and dialkyl phthalates. Bull Environ Contam Toxicol 6(3):200–204.5153760
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*McFall JA, Antoine, SR, DeLeon IR. 1985a. Base-neutral extractable organic pollutants in biota and sediments from Lake Pontchartrain. Chemosphere 14(10):1561–1569.
*McFall JA, Antoine SR, DeLeon IR. 1985b. Organics in the water column of Lake Pontchartrain. Chemosphere 14(9):1253–1265.
*Melnick RL, Schiller CM. 1985. Effect of phthalate esters on energy coupling and succinate oxidation in rat liver mitochondria. Toxicology 34:13–27.3969678
*Mes J, Coffin DE, Campbell DS. 1974. Di-n-butyl and di-2-ethylhexyl phthalate in human adipose tissue. Bull Environ Contam Toxicol 12(6):721–725.4457184
Metcalf RL. 1991. Insect control technology. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 590, 600.
*Meylan W, Howard P. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Michael LC, Pellizari ED. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Milkov LE, Aldyreva MV, Popova TB, . 1973. Health status of workers exposed to phthalate plasticizers in the manufacture of artificial leather and films based on PVC resins. Environ Health Perspect 3:175–178.4704567
*Milligan SR, Balasubramanian AV, Kalita JC. 1998. Relative potency of xenobiotic estrogens in an acute in vivo mammalian assay. Environ Health Perspect 106(1):23–26.9417770
*Moody DE, Reddy JK, Lake BG, . 1991. Peroxisome proliferation and nongenotoxic carcinogenesis: Commentary on a symposium. Fund Appl Toxicol 16(2):233–248.
Morrissey RE, Lamb JC, Schwetz BA, . 1988. Association of sperm, vaginal cytology, and reproductive organ weight data with results of continuous breeding reproduction studies in Swiss (CD-1) mice. Fundam Appl Toxicol 11:359–371.3220213
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Murakami K, Nishiyama K, Higuti T. 1986a. Toxicity of dibutyl phthalate and its metabolites in rats. Nippon Eiseigaku Zasshi (Jpn J Hyg) 41(4):775–781.
*Murakami K, Nishiyama K, Higuti T. 1986b. Mitochondrial effect of orally administered dibutyl phthalate in rats. Nippon Eiseigaku Zasshi (Jpn J Hyg) 41(4):769–774.
*Murature DA, Tang SY, Steinhardt G, . 1987. Phthalate esters and semen quality parameters. Biomed Environ Mass Spectrom 14:473–477.2957007
*Murray HE, Ray LE, Giam CS. 1981. Analysis of marine sediment, water and biota for selected organic pollutants. Chemosphere 10(11/12):1327–1334.
Mylchreest E, Cattley RC, Foster PMD. 1998a. Di(n-butyl) phthalate disrupts prenatal andro-genregulated male reproductive development in a manner different from flutamide. Toxicologist 42(1-S):176.
*Mylchreest E, Cattley RC, Foster PMD. 1998b. Male reproductive tract malformations in rats following gestational and lactational exposure to di(n-butyl) phthalate: An antiandrogenic mechanism? Toxicol Sci 43:47–60.9629619
*Mylchreest E, Sar M, Cattley RC, . 1999. Disruption of androgen-related male reproductive development by di(n-butyl) phthalate during late gestation in rats is different from flutamide. Toxicol Appl Pharm 156:81–95.
*Mylchreest E, Wallace DG, Cattley RC, . 2000. Dose-dependent alterations in androgen-regulated male reproductive development in rats exposed to di(n-butyl) phthalate during late gestation. Toxicol Sci 55:143–151.10788569
NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1988. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, National Air Toxics Information Clearinghouse. EPA-450/5-88-007. NTIS No. PB 89-106983.
Natusch DF, Tomkins BA. 1978. Isolation of polycyclic organic compounds by solvent extraction with dimethyl sulfoxide. Anal Chem 50:1429–1434.
Nematollahi J, Guess WL, Autian J. 1967. Plasticizers in medical application. I. Analysis and toxicity evaluation of dialkyl benzenedicarboxylates. J Pharm Sci 56:1446–1453.4293975
Nerín C, Cacho J, Gancedo P. 1993. Platicizers from printing inks in a selection of food packagings and their migration to food. Food Addit Contam 10(4):453–460.8405584
*NIEHS. 1994. Prestart toxicokinetic study report: di-n-butyl phthalate (DBP) in rodent plasma. Research Triangle Park, NC: National Institute of Environmental Health Sciences. NIH contract no. N01-ES-15307.
*NIEHS. 1995. Toxicokinetic study report: The Toxicokinetics and metabolism of di-n-butyl phthalate. Research Triangle Park, NC: National Institute of Environmental Health Sciences. NIH contract no. NIH contract no. N01-ES-15307.
*NIH. 1999. Toxicology and environmental health information. National Institute of Health, National Library of Medicine. http://chem.sis.nlm.nih.gov. May 23, 1999.
*Nikonorow M, Mazur H, Piekacz H. 1973. Effect of orally administered plasticizers and polyvinyl chloride stabilizers in the rat. Toxicol Appl Pharmacol 26:253–259.4751104
NIOSH. 1977. Health hazard evaluation/toxicity determination report 76-92-363, Jeffery Bigelow Design Group, Inc., Washington, DC. Cincinnati, OH: National Institute for Occupational Safety and Health. NIOSH-TR-HHE-76-92-36. NTIS No. PB-273913.
NIOSH. 1985a. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
NIOSH. 1985b. Dibutyl phthalate and di(2-ethylhexyl) phthalate - method 5020. In: NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health.
*NIOSH. 1988a. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1988b. National occupational hazard survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
*NIOSH. 1994. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1995. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
*NIOSH. 1997. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1999a. Acute toxicity data. Cincinnati, OH. National Institute for Occupational Safety and Health.
NIOSH. 1999b. Pocket guide to chemical hazards. Washington DC: National Institute for Occupational Safety and Health, U.S. Department of Health and Human Services.
*NIOSH. 2001. Pocket guide to chemical hazards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0187.html. January 8, 2001.
*Nishikawa H, Katami T, Takahara Y, . 1992. Emission of organic compounds by combustion of waste plastics involving chloride polymer. Chemosphere 25(12):1953–1960.
NLM. 1988. Chemline. National Library of Medicine, Bethesda, MD. December 1988.
Norpoth K. 1983. Phthalates. In: Parmeggiani L, ed. Encyclopedia of occupational health and safety. 3^rd^ ed. Vol. 2. Geneva, Switzerland: International Labour Office, 1690–1693.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
*NTP. 1984. Di(n-butyl) phthalate: Reproduction and fertility assessment in CD-1 mice when administered in the feed. Research Triangle Park, NC: National Institute of Environmental Health Science, National Toxicology Program. NTP 84-411. NTIS No. PB85-144798.
*NTP. 1995. Toxicity studies of dibutyl phthalate (CAS no. 84-74-2) administered in feed to F344/N and B6C3F1 mice. National Toxicology Program Toxicity Report Series, 30. Research Triangle Park, NC: National Toxicology Program/National Institutes of Health.
*NTP. 2000. NTP-CERHR expert panel report on dinbutyl phthalate. Alexandria, VA: Center for the Evaluation of Risks to Human Reproduction, U.S. Department of Health and Human Services, National Toxicology Program. NTP-CERHR-DBP-00.
*Nyssen GA, Miller ET, Glass TF, . 1987. Solubilities of hydrophobic compounds in aqueousorganic solvent mixtures. Environ Monit Assess 9:1–11.24254096
Oehme M. 1985. Negative ion chemical ionization mass spectrometry—a useful technique for the selective detection of polar substituted polycyclic aromatic hydrocarbons with mutagenic properties. Chemosphere 14:1285–1297.
*O’Grady DP, Howard PH, Werner AF. 1985. Activated sludge biodegradation of 12 commercial phthalate esters. Appl Environ Microbiol 49(2):443–445.16346734
Ohta Y, Nakamoto M. 1979. Metabolism of di-n-butyl phthalate by Aeromonas sp. Hakko Kogaku Kaishi 57:50–53.
*Oishi S, Hiraga K. 1980a. Effect of phthalic acid esters on mouse testes. Toxicol Lett 5:413–416.7394838
*Oishi S, Hiraga K. 1980b. Testicular atrophy induced by phthalic acid esters: Effect on testosterone and zinc concentrations. Toxicol Appl Pharmacol 53:35–41.7385236
Okada S, Tamemasa O. 1978. [Distribution and metabolism of di-(n-butyl)-phthalate in mice and its interaction with nucleic acids and proteins.] Yakugaku Zasshi 98:1229–1235. (Japanese)731395
OSHA. 1989. U.S. Department of Labor. Occupational Safety and Health Administration: Part III. Federal Register. 54:2332–2983.
OSHA. 1998a. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1998b. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55.
OSHA. 1998c. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000.
OSHA. 1999. Safety and health regulations for construction: Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_99/29cfr1926_99.html. February 2, 2001.
OSHA. 2000a. Occupational safety and health standards: Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_99/29cfr1910a_99.html. February 2, 2001.
OSHA. 2000b. Occupational safety and health standards for shipyard employment: Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. http://www.access.gpo.gov/nara/cfr/waisidx_00/29cfr1915_00.html. February 7, 2001.
*OSHA. 2001a. Air contaminants. Occupational and Safety & Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.slc.gov/OshStd_data/1915_1000.html. April 5, 2001.
*OSHA. 2001b. Gases, vapors, fumes, dusts, and mists. Occupational Safety & Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha:slc.gov/OshStd_toc/OSHA_Std_toc_1926.html. April 5, 2001.
*OSHA. 2001c. Limits for air contaminants. Occupational and Safety & Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1910.1000, (Table Z-1). http://www.osha-slc.gov/OshStd_data/1910_1000_TABLEZ-1.html. April 5, 2001.
*Otson R, Davis C, Fellin P, . 1991. Source apportionment for PAH in indoor air (northern climates). In: Cooke M, . eds. Polynuclear aromatic hydrocarbons: Measurement means, and metabolism, International Symposium, 11^th^ ed. Columbus, OH: Battelle Press, 667–685.
Overcash MR, Weber JB, Miles ML. 1982. Behavior of organic priority pollutants in the terrestrial system: di-n-butyl phthalate ester, toluene, and 2,4-dinitrophenol. Raleigh, NC: North Carolina State University, Water Resources Research Institute. UNC-WRRI-82-171.
Overturf ML, Druilhet RE, Liehr JG, . 1979. Phthalate esters in normal and pathological human kidneys. Bull Environ Contam Toxicol 22:536–542.486754
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 222–238.
Packham RF, Beresford SA, Fielding M. 1981. Health related studies of organic compounds in relation to re-use in the United Kingdom. Sci Total Environ 18:167–186.7233159
Pancorbo OC, Varney TC. 1986. Fate of synthetic organic chemicals in soil-groundwater systems. Vet Hum Toxicol 28:127–143.3518221
*Pankow JF, Ligocki MP, Rosen ME, . 1988. Adsorption/thermal desorption with small cartridges for the determination of trace aqueous semivolatile organic compounds. Anal Chem 60:40–47.
Petrasek AC, Kugelman IJ, Austern BM, . 1983. Fate of toxic organic compounds in wastewater treatment plants. J Water Pollut Control Fed 55(10):1286–1296.
PHRED. 1988. Public Health Risk Evaluation Database. U.S. Environmental Protection Agency, Washington, DC. March 1988.
Pizzoli M, Scandola M, Ceccorulli G, . 1985. Rate of absorption of di-n-butyl phthalate in glassy poly(vinylchloride). Polym Comm 26:107–109.
*Pocius AV. 1991. Adhesives. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol 1. New York NY: John Wiley & Sons, 445–466.
*Popp JA, Marsman DS, Cattley RC, . 1989. Hepatocarcinogenicity and peroxisome proliferation. CIIT Activities 9(3):1–7.
*Preston MR, Al-Omaran LA. 1986. Dissolved and particulate phthalate esters in the River Mersey Estuary. Marine Pollut Bull 17(12):548–553.
*Preston MR, Al-Omaran LA. 1989. Phthalate ester speciation in estuarine water, suspended particulates and sediments. Environ Pollut 48:183–193.
*Poulin P, Krishnan K. 1995. An algorithm for predicting tissue: Blood partition coefficients of organic chemicals from n-octanol: water partition coefficient data. J Toxicol Environ Health 46:117–129.7666490
*Pugh GJ, Isenberg JS, Kamendulis LM, . 2000. Effects of di-isononyl phthalate, di-2-ethylhexyl phthalate, and clofibrate in cynomolgus monkeys. Toxicol Sci 2000:181–188.
*Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Rao MS, Reddy JK. 1987. Peroxisome proliferation and hepatocarcinogenesis. Carcinogenesis 8:631–636.3555880
*Rastogi SC. 1998. Gas chromatographic analysis of phthalate esters in plastic toys. Chromatographia 47(784):724–726.
*Ray LE, Murray HE, Giam CS. 1983. Organic pollutants in marine samples from Portland, Maine. Chemosphere 12(7/8):1031–1038.
Reddy JK, Rao MS, Lalwani ND, . 1987. Induction of hepatic peroxisome proliferation by xenobiotics. In: Fahimi HD, Sies H, eds. Peroxisomes in biology and medicine. Heidelberg West Germany: Springer-Verlag, 255–262.
*Rhodes C, Orton TC, Pratt IS, . 1986. Comparative pharmacokinetics and subacute toxicity of di(2ethylhexyl) phthalate (DEHP) in rats and marmosets: Extrapolation of effects in rodents to man. Environ Health Perspect 65:299–308.3086078
Rieger MM. 1991. Cosmetics. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 607, 616.
*Ritsema R, Cofino WP, Frintrop PLM, . 1989. Trace-level analysis of phthalate esters in surface water and suspended particulate matter by means of capillary gas chromatography with electron- capture and mass-selective detection. Chemosphere 18(11/12):2161–2175.
Rosenbaum AS, Axelrad DA, Woodruff TJ, . 1999. National estimates of outdoor air toxics concentrations. J Air Waste Manage Assoc 49:1138–1152.
Rowland IR, Cottrell RC, Phillips JC. 1977. Hydrolysis of phthalate esters by the gastro-intestinal contents of the rat. Food Cosmet Toxicol 15:17–21.852780
*Roy WR. 1994. Groundwater contamination from municipal landfills in the U.S.A.. In: Adriano DC, ed. Contaminated groundwaters. Northwood, UK: Sci Rev, 411–446.
*RTECS. 1999. Registry of Toxic Effects of Chemical Substances. National Institute for Occupational Safety and Health. April 19, 1999.
*Rubin RJ, Kozumbo W, Kroll R. 1979. Ames mutagenic assay of a series of phthalic acid esters: Positive response of the dimethyl and diethyl esters in TA 100 [Abstract]. Toxicol Appl Pharmacol 48:A133.
*Russell DJ, McDuffie B. 1986. Chemodynamic properties of phthalate esters: partitioning and soil migration. Chemosphere 15(8):1003–1021.
Saido K, Motohashi S, Kuroki T. 1980. Studies on the thermal decomposition of phthalic acid esters. Thermal decomposition of di-n-butyl phthalate and analysis of its decomposed products. Nihon Daigaku Yakugaku Kenkyu Hokoku 20:1–10.
*Saillenfait AM, Payan JP, Fabry JP, . 1998. Assessment of developmental toxicity, metabolism, and placental transfer of di-n-butyl phthalate administered to pregnant rats. Toxicol Sci 45:212–224.9848128
Salthouse TN, Matlaga BF, O’Leary RK. 1973. Microspectrophotometry of macrophage lysosomal enzyme activity: A measure of polymer implant tissue toxicity. Toxicol Appl Pharmacol 25:201–211.4715483
*Sanders HO, Mayer FL, Jr, Walsh DF. 1973. Toxicity, residue dynamics, and reproduction effects of phthalate esters in aquatic invertebrates. Environ Res 6:84–90.4745372
Sandmeyer EE. Kirwin CJ Jr. 1981. Esters. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. 3rd ed. Volume 2A: Toxicology. New York NY: John Wiley and Sons, 2344–2412.
Sax NI, Lewis RJ Sr, eds. 1987. Hawley’s condensed chemical dictionary. 11^th^ ed. New York NY: Van Nostrand Reinhold Company, 372.
*Schilling K, Kaufman W, Hildebrand B. 1992. Study on the oral toxicity of dibutyl phthalate in Wistar rats—administration via the diet over 3 months. BASF Corporation. Ludwigshafen, Germany. Microfiche No. OTS0535640; Document ID 86-920000903.
Schmid P, Schlatter C. 1985. Excretion and metabolism of di(2-ethylhexyl)-phthalate in man. Xenobiotica 15(3):251–256.4024660
*Scholz N, Diefenbach R, Rademacher I, . 1997. Biodegradation of DEHP, DBP, and DINP: Poorly water soluble and widely used phthalate plasticizers. Bull Environ Contam Toxicol 58:527–534.9060369
*Schouten MJ, Peereboom JW, Brinkman U. 1979. Liquid chromatographic analysis of phthalate esters in Dutch river water. Int J Environ Anal Chem 7:13–23.
*Schulsinger C, Mollgaard K. 1980. Polyvinyl chloride dermatitis not caused by phthalates. Contact Dermatitis 6:477–480.7214892
*Scott RC, Dugard PH, Ramsey JD, . 1987. In vitro absorption of some o-phthalate deters through human and rat skin. Environ Health Perspect 74:223–227.3691429
*Seed JL. 1982. Mutagenic activity of phthalate esters in bacterial liquid suspension assays. Environ Health Perspect 45:111–114.6754360
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of Physiology: Endocrinology V. Washington DC: American Physiological Society, 143–172.
Seth PK. 1982. Hepatic effects of phthalate esters. Environ Health Perspect 45:27–34.6754361
Shafer KH, Cooke M, DeRoos F, . 1981. WCOT capillary column GC/FT-IR and GC/MS for identifying toxic organic pollutants. Appl Spectrosc 35:469–472.
*Shahin MM, Von Borstel RC. 1977. Mutagenic and lethal effects of alpha-benzene hexachloride, dibutyl phthalate and trichloroethylene in Saccharomyces cerevisiae. Mutat Res 48:173–180.69268
Shanker R, Ramakrishna C, Seth PK. 1985. Degradation of some phthalic acid esters in soil. Environ Pollut (Series A) 39:1–7.
*Shea PJ, Weber JB, Overcash MR. 1982. Uptake and phytotoxicity of di-n-butyl phthalate in corn (Zea mays). Bull Environ Contam Toxicol 29:153–158.7126902
*Sheldon LS, Hites RA. 1979. Sources and movement of organic chemicals in the Delaware River. Environ Sci Technol 13(5):574–579.
*Shelton DR, Tiedje JM. 1984. General method for determining anaerobic biodegradation potential. Appl Environ Microbiol 47(4):850–857.6721493
*Shibata K, Motooka K, Murata K, . 1982. Increase in growth rate and activity of the trytophan-NAD pathway caused by di-n-butyl phthalate in rats fed on a tryptophan-limited diet. J Nutr Sci Vitaminol 28:173–177.7119907
Shibko SI, Blumenthal H. 1973. Toxicology of phthalic acid esters used in food-packaging material. Environ Health Perspect 3:131–137.4704561
*Shiota K, Nishimura H. 1982. Teratogenicity of di(2-ethylhexyl) phthalate (DEHP) and di-n-butyl phthalate (DBP) in mice. Environ Health Perspect 45:65–70.7140698
Shiota K, Chou MJ, Nishimura H. 1980. Embryotoxic effects of di-2-ethylhexyl phthalate (DEHP) and di-n-butyl phthalate (DBP) in mice. Environ Res 22:245–253.7418682
*Shiu WY, Ma KC, Mackay D, . 1990. Solubilities of pesticide chemicals in water part II: Data compilation. Rev Environ Contam Toxicol 116:15–187.2205893
Shono T, Suita S. 2000. Letter to the editor. Toxicol Appl Pharmacol 164:336.10799345
Shono T, Kai H, Suita S, . 2000. Time-specific effects of mono-n-butyl phthalate on the transabdominal descent of the testis in rat fetuses. BJU Int 86(1):121–125.10886095
*Short RD, Robinson EC, Lington AW, . 1987. Metabolic and peroxisome proliferation studies wuth di(2-ethylhexel)phthalate in rats and monkeys. Toxicol Ind Health 3(1):185–195.3617067
Singh AR, Lawrence WH, Autian J. 1972. Teratogenicity of phthalate esters in rats. J Pharm Sci 61:51–55.5058645
Singh AR, Lawrence WH, Autian J. 1973. Embryonic-fetal toxicity and teratogenic effects of adipic acid esters in rats. J Pharm Sci 62:1596–1600.4796182
Sittig M, ed. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2^nd^ ed. Park Ridge, NJ: Noyes Publications, 311–312.
*Smith CC. 1953. Toxicity of butyl stearate, dibutyl sebacate, dibutyl phthalate, and methoxyethyl oleate. AMA Arch Ind Hyg Occup Med 7:310–318.13039587
*Smith RM. 1988. Supercritical fluid chromatography. Anal Chem 60(24):1394A.
SRI. 1985. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International, 799.
SRI. 1986. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International, 9055.
SRI. 1987. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International, 889.
SRI. 1988. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International, 870.
*SRI. 1998. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International, 870.
*SRI. 2000. Directory of chemical producers. Stanford Research Institute. United States of America. Menlo Park, CA: SRI International.
*Srivastava S, Singh GB, Srivastaba SP, . 1990. Testicular toxicity of di-n-butyl phthalate in adult rats: Effect on marker enzymes of spermatogenesis. Indian J Exp Biol 28:67–70.2365410
Stahlschmidt-Allner P, Allner B, Rombke J, . 1997. Endocrine disrupters in the aquatic environment. Environ Sci Pollut Res Int 4:155–162 19002402
*Stalling DL, Hogan JW, Johnson JL. 1973. Phthalate ester residues—their metabolism and analysis in fish. Environ Health Perspect 3:159–173.4145078
Staples CA, Parkerton TF, Peterson DR. 2000. A risk assessment of selected phthalate esters in North American and Western European surface waters. Chemosphere 40:885–891.10718582
*Staples C, Peterson D, Parkerton T, . 1997. The environmental fate of phthalate esters: A literature review. Chemosphere 35(4):667–749.
*STAPPA/ALAPCO. 1999. State and Territorial Air Pollution Program Administrators/Association of Local Air Pollution Control Officials. Washington, D.C. http://www.4cleanair.org/states.html#NorthC. May 6, 1999.
Steen WC, Paris DF, Baughman GL. 1980. Effects of sediment sorption on microbial degradation of toxic substances. Contaminants and Sediments 1:477–482.
Streufert JM, Jones JR, Sanders HO. 1980. Toxicity and biological effects of phthalate esters on midges (Chironomus plumosus). Trans Mo Acad Sci 14:33–40.
Stott WT. 1988. Chemically induced proliferation of peroxisomes: Implications for risk assessment. Regul Toxicol Pharmacol 8:125–159.3051140
*Stubin A, Bronsnan T, Porter K, . 1996. Organic priority pollutants in New York City municipal wastewaters: 1989-1993. Water Environ Res 68(6):1037–1044.
Sugawara N. 1974. Toxic effect of a normal series of phthalate esters on the hatching of shrimp eggs. Toxicol Appl Pharmacol 30:87–89.
*Sullivan KF, Atlas EL, Giam C-S. 1982. Adsorption of phthalic acid esters from seawater. Environ Sci Technol 16:428–432.22276761
*Swann R, Laskowski D, McCall P, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:18–28.
*Swartz RC, Schults DW, Ditsworth GR, . 1983. Sediment toxicity, contamination, and macrobenthic communities near a large sewage outfall. In: Boyle TP, ed. Validation and predictability of laboratory methods for assessing the fate and effects of contaminants in aquatic ecosystems. Philadelphia, PA: ASTM, 152–175.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tagatz ME, Plaia GR, Deans CH. 1986. Toxicity of dibutyl phthalate-contaminated sediment to laboratory- and field-colonized estuarine benthic communities. Bull Environ Contam Toxicol 37:141–150.3719139
*Takahashi T, Tanaka A. 1989. Biochemical studies on phthalic esters. V. Comparative studies on in vitro hydrolysis of di-n-butyl phthalate isomers in rats. Arch Toxicol 63:72–74.2742505
*Tanaka A, Matsumoto A, Yamaha T. 1978. Biochemical studies on phthalic esters. III. Metabolism of dibutyl phthalate (DBP) in animals. Toxicology 9:109–123.653732
*Tanino M, Ikemoto I, Tanaka A. 1987. Enzyme levels in rat testis damaged experimentally with dibutyl phthalate. Jikeikai Med J 34:245–252.
Tavares IA, Vine ND. 1985. Phthalic acid esters inhibit arachidonate metabolism by rat peritoneal leucocytes. J Pharm Pharmacol 37:67–68.2858534
Tavares IA, Bennett A, Gaffen JD, . 1984. The biological activities of phthalate esters on rat gastric muscle. Eur J Pharmacol 106:449–452.6597777
Taylor BF, Curry RW, Corcoran EF. 1981. Potential for biodegradation of phthalic acid esters in marine regions. Appl Environ Microbiol 42(4):590–595.16345856
Tesk JA, Antonucci JM, Eichmiller FC, . 1991. Dental materials. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York NY: John Wiley & Sons, 1002, 1014.
*Tesk JA, Antonucci J, Eichmiller F, . 1993. Dental materials. In: Kroschwitz, ed. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons Inc., 1002–1022
Thomas JA, Wienckowski DB, Gillies BA, . 1986. Effects of phthalic acid esters (PAEs) on the neonate and aspects of teratogenic actions. Environ Health Perspect 65:243–248.3709448
*Thurén A. 1986. Determination of phthalates in aquatic environments. Bull Environ Contam Toxicol 36:33–40.3940564
*Thurén A, Larsson P. 1990. Phthalate esters in the Swedish atmosphere. Environ Sci Technol 24:554–559.
Timofievskaya LA, Balynina ES. 1979. [Neurotoxic action of some o-phthalic acid esters.] Toksikol Nov Prom Khim Veshchestv 15:123–128. (Russian)
*Towae, FK, Enke, W,J, Jäckh, R, Bhargava, N. 1992. Phthalic acid and derivatives. In: Elvers B, Hawkins S, Schultz G, eds. Ullmann’s encyclopedia of industrial chemistry. 5^th^ ed. Volume A20. Weinheim, Germany: VCH Verlagsgesellschaft, 439–457.
TRI96. 1999. Toxic Chemical Release Inventory. National Library of Medicine, national Toxicology Information Program, Bethesda, MD.
*TRI98. 2000. TRI Explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. May 16, 1999.
*TRI99. 2001. TRI Explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. May 15, 2001.
*UATW. 1999. Unified Air Toxics Website. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. http://www.epa.gov/ttnuatw1/uatwn.html. May 6, 1999.
Urushigawa Y, Yonezawa Y. 1979. Chemico-biological interactions in biological purification systems: VI. Relation between biodegradation rate constants of di-n-alkyl phthalate esters and their retention times in reverse phase partition chromatography. Chemosphere 8:317–320.
*USC. 2001. Hazardous air pollutants. U.S. Code. 42USC4712. http://www.4law.cornell.edu/uscode/42/7412.text.html. April 4, 2001.
USDC. 1994. United States Department of Commerce. U.S. merchandise trade: exports, general imports, and imports for consumption: January 1994. FT925/94-1.
*USITC. 1980. Synthetic organic chemicals- United States production and sales, 1979. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1099.
*USITC. 1981. Synthetic organic chemicals- United States production and sales, 1980. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1183.
*USITC. 1982. Synthetic organic chemicals- United States production and sales, 1981. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1292.
*USITC. 1983. Synthetic organic chemicals- United States production and sales, 1982. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1422.
*USITC. 1984. Synthetic organic chemicals- United States production and sales, 1983. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1588.
*USITC. 1985. Synthetic organic chemicals- United States production and sales, 1984. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1745.
*USITC. 1986a. Synthetic organic chemicals- United States production and sales, 1985. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 1892.
*USITC. 1986b. Synthetic organic chemicals- United States production and sales, 1986. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2009.
*USITC. 1987. Synthetic organic chemicals- United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2118.
*USITC. 1988. Synthetic organic chemicals - United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2219.
*USITC. 1989. Synthetic organic chemicals - United States production and sales, 1989. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2338.
*USITC. 1990. Synthetic organic chemicals - United States production and sales, 1990. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2470.
*USITC. 1991. Synthetic organic chemicals - United States production and sales, 1991. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2607.
*USITC. 1992. Synthetic organic chemicals - United States production and sales, 1992. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2720.
*USITC. 1993. Synthetic organic chemicals - United States production and sales, 1993. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2810.
*USITC. 1994. Synthetic organic chemicals- United States production and sales, 1994. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2810.
*USITC. 1995. Synthetic organic chemicals- United States production and sales, 1994. Washington, DC: U.S. International Trade Commission. USITC Pub. No. 2810.
van Wezel AP, van Vlaardigen P, Posthumus R, . 2000. Environmental risk limits for two phthalates, with special emphasis on endocrine disruptive properties. Ecotoxicol Environ Saf 46:305–321.10903828
Verschueren K, ed. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 468–471.
*Verschueren K, ed. 1996. Dibutylphenylphosphate. In: Handbook of environmental data on organic chemicals 3^rd^ ed. New York, NY: Van Nostrand Reinhold, 641–646.
Vicedo JL, Pellin M, Vilanova E. 1985. Phthalates and organophosphorus compounds as cholinesterase inhibitors in fractions of industrial hexane impurities. Arch Toxicol 57:46–52.4015398
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
VIEW Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. June 20, 1989.
Virgin HI. 1988. Accumulation of di-n-butyl phthalate in plants and its effect on pigment and protein content. Physiologia Plantarum 72:190–196.
Wahl HG, Hoffmann A, Häring H-U, . 1999. Identification of plasticizers in medical products by a combined direct thermodesorption-cooled injection system and gas chromatography-mass spectrometry. J Chromatogr A847:1–7.
Wallace D. 1999. Consumer exposures to plasticizers and other migrants. Organohalogen Compounds 44:285–288.
Walseth F, Nilsen OG. 1981. Reversibility of the effects of dibutyl phthalate (DBP) on rat liver and lung microsomal enzyme activities and serum protein levels. Acta Pharmacol Toxicol 49(Part 1):90.
*Walseth F, Nilsen OG. 1984. Phthalate esters: II. Effects of inhaled dibutyl phthalate on cytochrome P-450 mediated metabolism in rat liver and lung. Arch Toxicol 55:132–136.6089701
*Walseth F, Nilsen OG. 1986. Phthalate esters: Effects of orally administered dibutylphthalate on cytochrome P-450 mediated metabolism in rat liver and lung. Acta Pharmacol Toxicol 59:263–269.
*Walters SM. 1986. Cleanup of samples. In: Zweig G, Sherma J, eds. Analytical methods for pesticides and plant growth regulators. Vol 15. Principles statistics, and applications. New York, NY: Academic Press, Inc., 67–110.
Wang Z, Zhang Y. 1989. [The study of toxicity of DBP to testis in rats. I. Target cell and time-effect relation.] Weisheng Dulixue Zazhi 3:25–28. (Chinese).
Ward JA. 1990. Studies of age-related testicular and reproductive endocrine toxicity of di-n-butyl phthalate in rats (testicular atrophy). [Abstract]. Diss Abstr Int B 52:782.
Weast RC, ed. 1985. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press Inc., C-430.
*Weiss G, ed. 1986. Dibutyl phthalate. In: Hazardous Chemicals Data Book 2^nd^ ed. Park Ridge, NJ: Noyes Data Corporation, 347.
*Weschler C, Sheilds H, Rainer D. 1990. Concentrations of volatile organic compounds at a building with health and comfort complaints. Am Ind Hyg Assoc J 51(5):261–268.2346114
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
White RD, Carter DE, Earnest D, . 1980. Absorption and metabolism of three phthalate deters by the rat small intestine. Food Cosmet Toxicol 18:383–386.7461517
*White RD, Earnest DL, Carter DE. 1983. The effect of intestinal esterase inhibition on the in vivo absorption and toxicity of di-n-butyl phthalate. Food Chem Toxicol 21(1):99–101.6681800
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
*Wieboldt RC, Adams GE, Later DW. 1988. Sensitivity improvement in infrared detection for supercritical fluid chromatography. Anal Chem 60:2422–2427.
Wilbourn J, Montesano R. 1982. An overview of phthalate ester carcinogenicity testing results: The past. Environ Health Perspect 45:127–128.7140684
Wilkinson SM, Beck MH. 1992. Allergic contact dermatitis from dibutyl phthalate, propyl gallate and hydrocortisone in Timodine. Contact Dermatitis 27:197.1451476
*Williams DT. 1973. Dibutyl- and di-(2-ethylhexyl) phthalate in fish. J Agric Food Chem 21(6):1128–1129.4755838
*Williams DT, Blanchfield BJ. 1975. The retention, distribution, excretion and metabolism of dibutyl phthalate-7-^14^C in the rat. J Agric Food Chem 23(5):854–858.1159183
Windholz M, Budavari S, eds. 1983. The Merck index: An encyclopedia of chemicals drugs, and biologicals. 10th ed. Rahway, NJ: Merck and Company, Inc., 219.
Wine R, Li L, Barnes L, . 1997. Reproductive toxicity of di-n-butyl phthalate in a continuous breeding protocol in Sprague-Dawley rats. Environ Health Perspect 105:102–107.9074889
*Wisconsin DNR. 2001. Draft working list: September 2000 NR 445 chemicals list. Wisconsin Department of Natural Resources. http://www.dnr.state.wi.us/org/aw/air/hot/nr445rev/draftchemlist092000.xls. February 8, 2001.
*Wofford HW, Wilsey CD, Neff GS, . 1981. Bioaccumulation and metabolism of phthalate esters by oysters, brown shrimp, and sheepshead minnows. Ecotoxicol Environ Saf 5:202–210.7250005
Wolfe NL, Burns LA, Steen WC. 1980b. Use of linear free energy relationships and an evaluative model to assess the fate and transport of phthalate esters in the aquatic environment. Chemosphere 9:393–402.
Wolfe NL, Paris DF, Steen WC, . 1980a. Correlation of microbial degradation rates with chemical structure. Environ Sci Technol 14:1143–1146.
Yamamoto S, Nakadate T, Aizu E, . 1990. Anti-tumor promoting action of phthalic acid mono-n-butyl ester cupric salt, a biomimetic superoxide dismutase. Carcinogenesis 11:749–754.2110512
Yanagita T, Enomoto N, Kuzuhara S. 1986. Effects of phthalate esters on liver lysosomal acid lipase and acid esterase in vitro. Agric Biol Chem 50:1653–1654.
Young LY, O’Connor O, Rivera MD. 1986. Toxic organic chemicals in waste streams: Anaerobic bioconversion to methane. Washington, DC: U.S. Department of Energy. DOE/CE/40657-1.
*Zacharewski TR, Meek MD, Clemons JH, . 1998. Examination of the in Vitro and in Vivo estrogenic activities of eight commercial phthalate esters. Toxicol Sci 46:282–293.10048131
*Zeiger E, Haworth S, Mortelmans K, . 1985. Mutagenicity testing of di (2-ethylhexyl) phthalate and related chemicals in Salmonella. Environ Mutagen 7:213–232.3971959
Zeiger E, Haworth S, Speck W. 1982. Phthalate ester testing in the National Toxicology Program’s environmental mutagenesis test development program. Environ Health Perspect 45:99–101.6754365
*Zhou Y, Fukuoka M, Tanaka A. 1990. Mechanisms of testicular atrophy induced by di-n-butyl phthalate in rats. Part 3. Changes in the activity of some enzymes in the sertoli and germ cells, and in the levels of metal ions. J Appl Toxicol 10(6):447–453.2128091
*Ziegler E, Edwards BB, Jensen RL . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zlatkis A, Kim K. 1976. Column elution and concentration of volatile compounds in biological fluids. J Chromatogr 126:475–485.977691