# PEER REVIEW

A peer review panel was assembled for di-n-butyl phthalate. The panel consisted of the following members:

1. William J. Adams, Ph.D., Kennecott Utah Copper Corporation, Magna, Utah;
2. Martin Alexander, Ph.D., Cornell University, Ithaca, New York;
3. C. Clifford Conaway, Ph.D., American Health Foundation, Valhalla, New York; and
4. Robert Rubin, Ph.D., Environmental Health Sciences, John Hopkins School of Public Health, Baltimore, Maryland

These experts have knowledge of di-n-butyl phthalate’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. These reviewers were selected in conformity with the conditions for peer review specified in Section 104(i)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.