# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding di-n-butyl phthalate in air, water, and other media are summarized in Table 8-1.

An MRL of 0.5 mg/kg/day has been derived for acute-duration oral exposure to di-n-butyl phthalate based on a NOAEL of 50 mg/kg/day for developmental effects in the offspring of rats orally exposed by gavage to di-n-butyl phthalate on gestational days 12–21 (Mylchreest et al. 2000).

A chronic MRL for DNB was not derived. There were no adequate chronic-duration oral studies identified for humans or animals. EPA verified an RfD of 0.1 mg/kg/day based on a study by Smith (1953) (IRIS 1999). In this study, 10 rats were fed diets containing 0.01-1.25 % dibutyl phthalate. Half of the high dose group died within the first week of exposure. ATSDR did not have confidence in this study to derive an MRL due to the lack of detail and apparent conflict in the reported results. EPA also had low confidence in the study; the RfD received a low rating.

The health effects data for di-n-butyl phthalate were evaluated by EPA and determined to be inadequate for derivation of an inhalation RfC; the RfC is considered not verifiable (IRIS 1999).

Table 8-1 Regulations and Guidelines Applicable to Di-n-butyl Phthalate

Agency | Description | Information | References
INTERNATIONAL
Guidelines:
IARC | Carcinogenic classification | No data
NATIONAL
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA | 5 mg/m^3^ | ACGIH 2000
EPA | RAC | 100 μg/m^3^ | EPA 2001p; 40CFR266; Appendix IV
NIOSH | REL (TWA) | 5 mg/m^3^ | NIOSH 2001
NIOSH | IDLH | 4,000 mg/m^3^ | NIOSH 2001
OSHA | PEL (8-hour TWA) General industry | 5 mg/m^3^ | OSHA 2001c; 29CFR1910.1000; Table Z-1
OSHA | PEL (8-hour TWA) Construction industry | 5 mg/m^3^ | OSHA 2001b; 29CFR1926.55; Appendix A
OSHA | PEL (8-hour TWA) Shipyard industry | 5 mg/m^3^ | OSHA 2001a; 29CFR1915.1000
USC | HAP | | USC 2001; 42USC7412
b. Water
DOT | Marine pollutant | | DOT 2001b; 49CFR172.101; Appendix B
EPA | Effluent guidelines—aluminum forming point source category TTO | >0.01 mg/L | EPA 2001h; 40CFR467.02
EPA | Effluent guidelines—coil coating point source category TTO | >0.01 mg/L | EPA 2001g; 40CFR465.02
EPA | Effluent guidelines—metal finishing point source category TTO | >0.01 mg/L | EPA 2001q; 40CFR433.11
EPA | Effluent guidelines; steam electric power generating point source category—priority pollutants | | EPA 2001o; 40CFR423; Appendix A
EPA | Human health consumption | | EPA 1999c
EPA | Water and organism | 2.7 mg/L | EPA 1999c
EPA | Organism only | 12 mg/L | EPA 1999c
EPA | NPDES—permit application testing requirements | Organic toxic pollutants in each of four fractions in analysis by GC/MS volatiles | EPA 2001l; 40CFR122; Appendix D; Table II
EPA | NPDES—permit testing requirements for publicly owned treatment works | | EPA 2001m; 40CFR122; Appendix J; Table 2
EPA | Process waste water discharges resulting from the manufacture of bulk organic chemicals | | EPA 2001a; 40CFR414.70
EPA | Standards for owners/operators of hazardous waste TSD facilities— groundwater monitoring (PQL) | 5 μg/L | EPA 2001i; 40CFR264; Appendix IX
EPA | Toxic pollutant effluent limitations and standards for direct discharge point sources that use end-of-pipe biological treatments—effluent limitations | | EPA 2001u; 40CFR414.91(b)
EPA | Maximum for any 1-day | 57 μg/L | EPA 2001u; 40CFR414.91(b)
EPA | Maximum for any monthly average | 27 μg/L | EPA 2001u; 40CFR414.91(b)
EPA | Toxic pollutant effluent limitations and standards for direct discharge point sources that do not use end-of-pipe biological treatments—effluent limitations | | EPA 2001v; 40CFR414.101(b)
EPA | Maximum for any 1-day | 43 μg/L | EPA 2001v; 40CFR414.101(b)
EPA | Maximum for any monthly average | 20 μg/L | EPA 2001v; 40CFR414.101(b)
EPA | Toxic pollutant standards for indirect discharge point sources—effluent limitations | | EPA 2001w; 40CFR414.111(b)
EPA | Maximum for any 1-day | 43 μg/L | EPA 2001w; 40CFR414.111(b)
EPA | Maximum for any monthly average | 20 μg/L | EPA 2001w; 40CFR414.111(b)
EPA | Water quality standards—toxics criteria for those states not complying with Clean Water Act Section 303(c)(2)(B) | No data | EPA 2001t; 40CFR131.36
c. Food
FDA | Indirect food additive— adhesives and components of coating | | FDA 2000a; 21CFR175.105
FDA | Indirect food additive— adhesives and components of coatings; catalysts and crosslinking agents for epoxy resins | For use only in coatings for containers having a capacity of 1,000 gallons or more when intended for repeated use in contact with alcoholic beverages containing up to 8% of alcohol by volume | FDA 2000f; 21CFR175.300(b)
FDA | Indirect food additive— limitations on cellophane for food packaging | Alone or in combination with other phthalates— total phthalates do not exceed 5% | FDA 2000b; 21 CFR 177.1200
FDA | Indirect food additive—paper and paperboard components | | FDA 2000d; 21CFR176.170
FDA | Indirect food additive—paper and paperboard components | Adjuvant substances permitted to be used in the preparation of slimicides | FDA 2000g; 21CFR176.300(d)
FDA | Indirect food additive—polyester resins, cross-linked; solvents for inhibitors, accelerators, and catalysts | Quantity used does not exceed that reasonably required to accomplish intended physical or technical effect | FDA 2000e; 21CFR177.2420(b)
FDA | Indirect food additives—rubber articles intended for repeated use | Total not to exceed 30% by weight of rubber product | FDA 2000c; 21CFR177.2600
d. Other
ACGIH | BEI; Carcinogenic classification | No data | ACGIH 2000
CPSC | Consumer product limits | No data
DOT | Reportable quantity | 10 pounds | DOT 2001a; 49CFR172.101; Appendix A; Table 1
EPA | Carcinogenic classification | Group D^a^ | IRIS 2001
EPA | RfD | 0.1 mg/kg/day
EPA | Designated hazardous substance | | EPA 2001c; 40CFR116.4
EPA | Health and environmental protection standards for uranium and thorium mill tailings—listed constituent | | EPA 2001k; 40CFR192; Appendix I
EPA | Identification and listing of hazardous waste | U069 | EPA 2001f; 40CFR261.33
EPA | Land disposal restrictions— universal treatment standards | | EPA 2001x; 40CFR268.48(a)
EPA | Wastewater standard | 0.057 mg/L^2^ | EPA 2001x; 40CFR268.48(a)
EPA | Nonwastewater standard | 28 mg/kg^3^ | EPA 2001x; 40CFR268.48(a)
EPA | Municipal solid waste landfills— hazardous inorganic and organic constituents | | EPA 2001j; 40CFR258; Appendix II
EPA | Suggested method | 8060 8270 | EPA 2001j; 40CFR258; Appendix II
EPA | PQL | 5 μg/L 10 μg/L | EPA 2001j; 40CFR258; Appendix II
EPA | Pollutants eligible for a removal credit | If requirements for total hydrocarbons are met when sewage sludge is fired in a sewage sludge incinerator | EPA 2001n; 40CFR403; Appendix G
EPA | Reportable quantity | 100 pounds | EPA 2001d; 40CFR302.4
EPA | Toxic chemical release reporting; Community Right-to-Know—effective date | 01/01/87 | EPA 2001b; 40CFR372.65
EPA | TSCA—health and safety data reporting; studies not subject to the reporting requirements | | EPA 2001r; 40CFR716.120(c)
EPA | TSCA—testing consent order for environmental effects | 01/09/89 | EPA 2001s; 40CFR799.5000
STATE
Regulations and Guidelines:
a. Air
Arkansas | RAC | 100 μg/m^3^ | BNA 2001
California | RAC | 100 μg/m^3^ | BNA 2001
Delaware | RAC | 100 μg/m^3^ | BNA 2001
Idaho | Toxic air pollutants | | BNA 2001
Idaho | OEL | 5.0 mg/m^3^ | BNA 2001
Idaho | EL | 0.333 pounds/hour | BNA 2001
Idaho | AAC | 0.25 mg/m^3^ | BNA 2001
Illinois | RAC | 100 μg/m^3^ | BNA 2001
Kansas | Ambient air quality standards | 10 tons/year | CDC 1999
Kentucky | RAC | 100 μg/m^3^ | BNA 2001
Minnesota | HAP threshold | 10 tons/year | BNA 2001
New Hampshire | Regulated toxic air pollutant | | BNA 2001
New Hampshire | OEL | 5 mg/m^3^ | BNA 2001
Rhode Island | HAP | | BNA 2001
South Carolina | RAC | 100 μg/m^3^ | BNA 2001
South Carolina | Toxic air emissions—maximum allowable concentration | 25 μg/m^3^ | BNA 2001
Tennessee | RAC | 100 μg/m^3^ | BNA 2001
Vermont | Hazardous ambient air standard | 500 μg/m^3^ | BNA 2001
Vermont | Averaging time | 8 hours | BNA 2001
Vermont | Action level (8-hours) | 21 pounds | BNA 2001
Wisconsin | <25 ft | 0.269 pounds/hour | Wisconsin DNR 2001
Wisconsin | 25 ft <75 ft | 1.04 pounds/hour | Wisconsin DNR 2001
Wisconsin | 75 ft | 8.11 pounds/hour | Wisconsin DNR 2001
Wisconsin | Ambient air concentrations | 120 μg/m^3^ | Wisconsin DNR 2001
Wyoming | RAC | 100 μg/m^3^ | BNA 2001
b. Water
Alaska | Groundwater clean-up level | 3.65 mg/L | BNA 2001
Arkansas | Goundwater monitoring (PQL) | 5 μg/L | BNA 2001
Delaware | Freshwater | | BNA 2001
Delaware | Fish ingestion only | 13 mg/L | BNA 2001
Delaware | Fish and water ingestion | 2.8 mg/L | BNA 2001
Delaware | Marine/Estuarine | | BNA 2001
Delaware | Fish and shellfish ingestion | 2.1 mg/L | BNA 2001
Florida | Drinking water guideline | 0.7 mg/L | HSDB 2001
Georgia | Instream concentration | 12.1 mg/L | BNA 2001
Illinois | Groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Kentucky | Hazardous constituents for groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Kentucky | Maximum allowable instream concentration | 2.7 mg/L | BNA 2001
Louisiana | Groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Maine | Drinking water guideline | 0.22 mg/L | HSDB 2001
Massachusetts | Groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Michigan | Groundwater quality treatment technology standard | 35 μg/L | BNA 2001
Minnesota | Drinking water guideline | 0.7 mg/L | HSDB 2001
Nebraska | Aquatic life criteria | | BNA 2001
Nebraska | Acute | No data | BNA 2001
Nebraska | Chronic | 12 mg/L | BNA 2001
New Hampshire | Drinking water guideline | 0.8 mg/L | HSDB 2001
New Hampshire | Water quality criteria | | BNA 2001
New Hampshire | Water and fish ingestion | 2.7 mg/L | BNA 2001
New Hampshire | Fish consumption only | 12 mg/L | BNA 2001
New Hampshire | Ambient groundwater quality standard | 34 mg/L | BNA 2001
New Jersey | Groundwater quality criteria | 900 μg/L | BNA 2001
New Jersey | PQL | 20 μg/L | BNA 2001
New Mexico | Groundwater parameter (PQL) | 0.01 mg/L | BNA 2001
New York | Groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Oklahoma | Hazardous constituent (PQL) | 5 μg/L | BNA 2001
South Carolina | Water quality criteria | | BNA 2001
South Carolina | Organism consumption | 12 mg/L | BNA 2001
South Carolina | Groundwater monitoring (PQL) | 5 μg/L | BNA 2001
Vermont | Consumption of water and organism | 2.7 mg/L | BNA 2001
Vermont | Consumption of organism only | 12 mg/L | BNA 2001
Virginia | Hazardous constituent (PQL) | 5 μg/L | BNA 2001
Virginia | Public water supply | 2.7 mg/L | BNA 2001
Virginia | All other surface waters | 12 mg/L
Wisconsin | Drinking water guideline | 0.1 mg/L | HSDB 2001
Wisconsin | Groundwater standard | | BNA 2001
Wisconsin | Enforcement standard | 100 mg/L | BNA 2001
Wisconsin | Preventive action limit | 20 mg/L | BNA 2001
c. Food | | No data
d. Other
Alabama | RfD | 0.1 mg/kg/day | BNA 2001
Delaware | Direct exposure criteria for soil | | BNA 2001
Delaware | Residential | 1,000 ppm | BNA 2001
Delaware | Industrial/commercial | 2,500 ppm | BNA 2001
Massachusetts | RfD | 0.1 mg/kg/day | BNA 2001
Minnesota | RfD | 0.1 mg/kg/day | BNA 2001
Minnesota | Health risk limit | 700 μg/L | BNA 2001
Missouri | Hazardous constituents | | BNA 2001
New York | Reportable quantity | | BNA 2001
New York | Air | 10 pounds | BNA 2001
New York | Land/water | 1 pound | BNA 2001

a Group D: inadequate or no human and animal evidence of carcinogenicity

AAC = acceptable ambient concentrations; ACGIH = American Conference of Governmental Industrial Hygienists; BEI = biological exposure index; BNA = Bureau of National Affairs; CDC = Center for Disease Control; CFR = Code of Federal Regulations; CPSC = Consumer Product Safety Commission; DNR = Department of Natural Resources; DOT = Department of Transportation; EL = emissions level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GC/MS = gas chromatography/mass spectroscopy; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health; IRIS = Integrated Risk Information System; NIOSH = National Institute of Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; OEL = occupational exposure level; OSHa = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation limit; RAC = reference air concentration; REL = recommended exposure limit; RfD = oral reference dose; TLV = threshold limit value; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TTO = total toxic organics; TWA = time-weighted average; USC = United States Code