# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of di-n-butyl phthalate is located in Table 4-1. Table 4-1 lists common synonyms, trade names, and other pertinent identification information for di-n-butyl phthalate.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of di-n-butyl phthalate is located in Table 4-2. Table 4-2 lists important physical and chemical properties of di-n-butyl phthalate, but is not intended to be all inclusive.

Table 4-1 Chemical Identity of Di-n-butyl Phthalate

Characteristic | Information | Reference
Chemical name | Di-n-butyl phthalate | HSDB 2000
Synonym(s) | 1,2-Benzenedicarboxylic acid, dibutyl ester; Butyl phthalate; DBP; Dibutyl-o-phthalate; Dibutyl phthalate; Phthalic acid butyl ester | HSDB 2000; Budavari 1996
Registered trade name(s) | Caswell No. 292; Celluflex DBP; Palatinol C; Polycizer DBP; PX 104; Staflex DBP; Uniflex DB | HSDB 2000
Chemical formula | C_16_H_22_O_4_ | Budavari 1996
Chemical structure | [image] | Metcalf 1994
Identification numbers:
CAS Registry | 84-74-2 | Lewis 1993
NIOSH RTECS | TI0875000 | HSDB 2000
EPA Hazardous Waste | U069 | EPA 1992
OHM/TADS | 7216617 | CIS 1999
DOT/UN/NA/IMCO | UN 2810/NA 9095 | DOT 1998
HSDB | 922 | HSDB 2000
NCI | 5804 | NIH 1999

CAS = Chemical Abstracts Services; CIS = Chemical Information System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Di-n-butyl Phthalate

Property | Information | Reference
Molecular weight | 278.34 | Budavari 1996
Color | Colorless to faint yellow | HSDB 1999
Physical state | Oily liquid | Lewis 1993
Melting point | −35 ° C | Verschueren 1996
Boiling point | 340 ° C | Budavari 1996
Density at 20 ° C | 1.04 kg/L | Ashford 1994
Odor | Slight ester-like | EPA 1993
Odor threshold:
Water | No data
Air | 0.26-1.47 mg/m^3^ | EPA 1980b
Taste | Strong and bitter taste | HSDB 1999
Solubility:
Water | 11.2 mg/L | Staples et al. 1997
Freshwater at 20 ° C | 10.1-11.1 mg/L | Shiu et al. 1990
Organic solvent (s) | Very soluble in alcohol, ether, acetone, and benzene | Budavari 1996
Partition coefficients:
Log K_ow_ | 4.72 | Hansch et al. 1995
Log K_ow_ | 4.45 | Staples et al. 1997
Log K_ow_ | 3.7 | de Bruijn et al. 1989
Log K_oc_ | 3.14 | Russell and McDuffie 1986
Log K_oc_ | 4.17 | Sullivan et al. 1982
Vapor pressure at 25 ° C | 2.01×10^−5^ mmHg | Donovan 1996
Vapor pressure at 25 ° C | 2.7×10^−5^ mm Hg | Staples et al. 1997
Polymerization | No data
Photolysis | No data
Henry’s law constant at 25 ° C | 4.5×10^−6^ atm-m^3^/mole | Roy 1994
Henry’s law constant at 25 ° C | 8.83×10^−7^ atm-m^3^/mole | Staples et al. 1997
Autoignition temperature | 403 ° C | Weiss 1986
Flashpoint | 157 ° C | NIOSH 1997
Flammability limits at 25 ° C | No data
Incompatibilities | Reacts explosively with liquid chlorine | Bisesi 1994
Conversion factors (25 ° C) | 11.36 mg/m^3^=approximately 1 ppm | Bisesi 1994
Conversion factors (25 ° C) | 1 mg/m^3^=0.088 ppm
Explosive limits | Lower explosive limit: 0.5% at 236 ° C | NIOSH 1997

HSDB = Hazardous Substance Data Bank; NIOSH = National Institute for Occupational Safety and Health