# APPENDIX A ATSDR MINIMAL RISK LEVEL AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Di-n-butyl phthalate Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Di-n-butyl phthalate
CAS Number: | 84-74-2
Date: | June 30, 2001
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to Figure: | 21
Species: | Rats

[underlined: Minimal Risk Level]: 0.5 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Mylchreest E, Wallace DG, Cattley RC, . 2000. Dose-dependent alterations in androgen-regulated male reproductive development in rats exposed to di(n-butyl) phthalate during late gestation. Toxicol Sci 55:143–151 10788569 .

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Groups of 20 pregnant Sprague-Dawley rats (except 11 in the 500 mg/kg/day group) were treated with 0, 0.5, 5, 50, 100, or 500 mg/kg/day di-n-butyl phthalate by gavage in corn oil on gestation days 12–21. Dams were examined daily for clinical signs of toxicity, body weight was recorded daily during treatment, and food intake was recorded twice weekly. Dams were killed on postpartum day 21, examined grossly, and the weights of liver, kidneys, adrenals, uterus, and ovaries, and numbers of implantation sites were recorded. On postpartum day 1, numbers of live and dead pups, clinical signs of toxicity, pup weight, and ano-genital distance were recorded. Additionally, the location and number of nipples and areolas were recorded for male pups on postpartum day 14. From postpartum day 30 (females) or 38 (males), pups were examined daily for vaginal opening or preputial separation, respectively, until occurrence. Pups were killed at sexual maturity (postpartum day 110±10 days for males; 80±5 days for females), weighed, and internal and external genitalia were examined for malformations and undescended testes. Organs were weighed, and right testis and epididymides were examined histologically.

[underlined: Effects noted in study and corresponding concentrations]: No developmental effects or clinical signs of toxicity were seen in pups exposed to 50 mg/kg/day or less in utero. The only treatment-related effect seen in the 100 mg/kg/day group was retained areolas and nipples in males (normally seen only in females) on postpartum day 14. This effect was dose-dependent, being more prominent at 500 mg/kg/day. Permanence of retained areolas and nipples was not assessed. Other statistically significant effects, seen only in males at 500 mg/kg/day level, were decreased AGD (12% decrease) and ano-genital distance/body weight at birth; smaller epididymides, dorsolateral prostate, and levator ani-bulbocavernosus muscle at sexual maturity; and decreased testes weight (when animals with enlarged testes were excluded). Malformations of the male reproductive tract included absent or malformed epididymis, absent or malformed vas deferens, hypospadia, and unilaterally absent seminal vesicle. Histopathological lesions of the testis seen were seminiferous tubule degeneration, focal interstitial hyperplasia, and adenoma. In males, no significant changes were seen in age at preputial separation, or body, kidney, liver, adrenal, ventral prostate, vas deferens, seminal vesicle, or other organ weights (other than those listed above). In female pups, no significant differences from controls were seen in age of onset of vaginal opening; body, liver, kidney, adrenal, ovary, or uterus weight; or gross morphology of the reproductive organs at sexual maturity.

[underlined: Concentration and end point used for MRL derivation]: Increased incidence of retained areolas and nipple in the male offspring of rats exposed to ≥100 mg/kg/day; no effects were observed at 50 mg/kg/day.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] A number of developmental effects involving androgenic-dependent tissues have been observed in acutely or longer exposed rats; these include decreases in anogenital distance and anogenital distance/body weight ratio, increased number of retained nipples, and decreased androgen-dependent tissue weights (ventral prostate, epididymis, cauda epididymis, testes, glans penis, and levator ani-bulbocavernosus) (Ema et al. 1998, 2000b; Gray et al. 1999; Mylchreest et al. 1999, 2000).

[underlined: Agency Contact (Chemical Manager):] Jessilynn Taylor