# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of diisopropyl methylphosphonate is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of diisopropyl methylphosphonate is located in Table 3-2.

TABLE 3-1 Chemical Identity of Diisopropyl Methylphosphonate

Characteristic | Information | Reference
Chemical name | Diisopropyl methylphosphonate | EPA 1989
Synonym(s) | DIMP; diisopropyl methanephosphonate; phosphonic acid; methyl-, bis-(1-methyl-ethyl) ester; phosphonic acid, methyl-diisopropyl ester | Dacre and Rosenblatt 1987
Registered trade name(s) | Not a commercial substance
Chemical formula | C_7_H_17_O_3_P | Dacre and Rosenblatt 1987
Chemical structure | [image] | Dacre and Rosenblatt 1987
Identification numbers:
CAS registry | 1445-75-6 | Dacre and Rosenblatt 1987
NIOSH RTECS | SZ9090000 | Dacre and Rosenblatt 1987
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | 6864 | HSDB 1994
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemicals Substances

TABLE 3-2 Physical and Chemical Properties of Diisopropyl Methylphosphonate

Property | Information | Reference
Molecular weight | 180.18 | Dacre and Rosenblatt 1987
| 180.21 | HSDB 1994
Color | Colorless | EPA 1989
Physical state | Liquid | EPA 1989
Melting point | No data
Boiling point | 174°C | EPA 1989
Density:
At 25°C | 0.976 g/mL | EPA 1989
Odor | No data
Odor threshold | No data
Solubility:
Water at 0°C | 80 g/L | Bucci et al. 1997
Water at 25°C | 1-2 g/L | Dacre and Rosenblatt 1987
Water at 80°C | Hg/L | Dacre and Rosenblatt 1987
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor pressure:
Temperature not specified | 10^−4^−1 mmHg | Rosenblatt et al. 1975a, 1975b
At 10°C | 13 (estimated) | Dacre and Rosenblatt 1987
At 100°C | 34 (estimated) | Dacre and Rosenblatt 1987
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | No data
Explosive limits | No data