# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Super-fund Amendments and Reauthorization Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the US. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect 1eveVuncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Diisopropyl Methylphosphonate Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Diisopropyl Methylphosphonate
CAS number: | 144-75-6
Date: | March 1998
Profile status: | Draft 2 - Postpublic Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 27
Species: | Dog

[underlined: Minimal Risk Level]: 0.8 mg/kg/day

[underlined: Reference:] Hart 1980

[underlined: Experimental design]: Purebred beagles, four males and four females, received diisopropyl methylphosphonate in the diet at concentrations of 150, 1,500, and 3,000 ppm (4, 38, or 75 mg/kg/day) for 90 days. A control group of four males and four females was also maintained. At the outset of the study and at 48, and 13 weeks, hemograms and clinical chemistry parameters were determined for all of the dogs. The dogs were examined daily for general condition. Food consumption and body weights were determined weekly. At the termination of the 90-day study each dog was necropsied and selected tissues preserved and examined for histopathological changes.

[underlined: Effects noted in studv and corresponding doses]:

The dogs appeared in good condition throughout the study. No hematological effects were ascribed to diisopropyl methylphosphonate. The authors concluded that the ingestion of diisopropyl methylphosphonate produced no toxic effects at the concentrations that the dogs received over the 90-day period of the study.

At the termination of the study a gross necropsy was performed on all of the dogs and no meaningful changes were observed. In addition, the liver, brain, thyroid, kidneys, adrenal glands, testes, ovaries, heart, and spleen were removed and weighed. No significant weight changes were noted. The liver, brain, thyroid, kidneys, adrenal glands, testes, ovaries, heart, spleen, spinal cord, lungs, pancreas stomach, small intestines, colon, urinary bladder, prostate, eyes with optic nerve, pituitary, marrow of the femur, rib junction, mesenteric lymph node, mammary tissue, skin, sciatic nerve, muscle, uterus, gall bladder, and any gross lesion of the 3000 ppm group and the control group were examined histologically and no clear or meaningful changes were noted.

[underlined: Dose and end uoint used for MRL derivation:]

[X] NOAEL [ ] LOAEL

75 mg/kg/day (3,000 ppm dietary concentration)

[underlined: Uncertainty Factors used in MRL derivation:]

- [X] 10 for human variability
- [X] 10 for extrapolation of from animals to humans

75 mg / kg / day ÷ 100 = 0.75 mg / kg / day

[underlined: Was a conversion used from num in food or water to a mg/bodv weight dose? If so. exolain:]

The doses of diisopropyl methylphosphonate that the dogs received in the diet (1.50, 1,500, and 3,000 ppm) were calculated using the recommended reference value of 0.025 kg food/kg body weight/day as follows:

( 3,000 ppm ) ( 0.025 kg / kg / day ) = 75 mg / kg / day

[underlined: Other additional studies or pertinent information which lend supoort to this MRL]:

Although this study (Hart 1980) did not identify an effect level, the NOAEL in this study is below the lowest-Observable-effect level (LOAEL) found in all studies examining the toxicity of diisopropyl methylphosphonate. The LOAEL for diisopropyl methylphosphonate is 345 mg/kg/day for male mink, and 455 mg/kg/day for female mink (average 400 mg/kg/day), doses at which statistically significant decreases in plasma (butyrylcholinesterase) but not RBC cholinesterase (acetylcholinesterase) activity was observed (Bucci et al. 1994). No effects were observed at 63 mg/kg/day in males and 82 mg/kg/day in females (average 73 mg/kg/day). A decrease in plasma cholinesterase activity is considered to be a marker of exposure rather than a marker of effect, while decreases in RBC acetylcholinesterase activity is thought to reflect decreases in brain acetylcholinesterase activity and is considered adverse.

Adverse effects, shortened RBC survival, increased Heinz body formation, increased number of reticulocytes, and reduced blood cell counts were observed at 747 mg/kg/day in males and 907 mg/kg/day in females (average 827 mg/kg/day). Although not statistically significant, the number of Heinz bodies was increased relative to controls at 400 mg/kg/day. The observed effects are consistent with a direct effect on RBC decreasing survival of the cells.

Metabolism studies in mink (Bucci et al. 1992) indicate that diisopropyl methylphosphonate is readily absorbed, metabolized to isopropylmethyl phosphonate, and excreted in the urine. After comparison with a metabolism study in dogs (Hart 1976), Bucci et al. (1992) concluded that mink handled the compound in a similar manner to dogs providing support for the use of mink when estimating risk to humans following diisopropyl methylphosphonate exposure. The metabolism study in mink (Bucci et al 1992) suggested that at high doses (≥270 mg/kg) the principal pathway of metabolism of diisopropyl methylphosphonate is saturable. In the metabolism study the animals were treated by gavage; therefore, the dose rates in the gavage and dietary dosing studies may not be directly comparable. Purther metabolism studies using dietary treatment are required to determine if the metabolism of diisopropyl methylphosphonate was saturated at the high doses (≥827 mg/kg/day) at which adverse effects on RBC were observed.

The Environmental Protection Agency derived a reference dose (RfD) of 0.08 mg/kg/day based on the same NOAEL from the Hart (1980) study. The RfD, however, utilized an additional uncertainty factor of 10 to extrapolate to chronic exposure.

## Diisopropyl Methylphosphonate Chronic Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Diisopropyl Methylphosphonate
CAS number: | 144-75-6
Date: | March 1998
Profile status: | Draft 2 - Postpublic Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 45
Species: | Mink

[underlined: Minimal Risk Level: 0.6 mg/kg/day]

[underlined: Reference:] Bucci et al. 1997

[underlined: Experimental design:] In a 2-generation reproductive study, Ranch Wild mink received 0, 16, 45, or 262 mg/kg/day (males) or 0, 20, 57, or 330 mg/kg/day (females) diisopropyl methylphosphonate in the diet. These dosages were calculated for F_1_ animals by the study authors using actual concentrations in the feed of 0, 168, 490, and 2,774 ppm diisopropyl methylphosphonate. F_1_generation females were treated for up to 13 months, while other generations and F_1_ males were treated for up to 8 months. Two groups of control animals were used. Animals were observed twice/day for clinical signs and were weighed weekly. In addition to standard examinations of body and organ weights, hematology, clinical chemistry, parental animals from both generations and representative kits underwent gross histopathological examination, which included reproductive organs in males and gross lesions and developmental defects in the kits. Reproductive parameters examined were live kits/litter, litter weight at birth and 28 days, and sex ratio. Ovarian follicles were also counted in high-dose females.

[underlined: Effects noted in studv and corresponding doses:]

No effects were observed in F_1_ females at 57 mg/kg/day that were attributable to diisopropyl methylphosphonate after 13 months of exposure. Altbough there was no significant difference in food consumption or body weight in either generation compared to controls, the F_1_ females consumed almost 50% more feed than the F_0_ females, but this may have resulted from feed wastage. There was no treatment related change in litter size, percentage live births, kit weight or sex distribution in either generation. However, at 330 mg/kg/day, Heinz body counts were increased in F_1_ females after 6 and 13 months and high-dose males of this generation had increased Heinz body counts. There was a 31% decrease in plasma cholinesterase in animals fed 330 mg/kg/day for 13 months, but this is not considered to be biologically significant. There was also a significant increase in ovarian follicles among animals at this concentration (the only level examined). However, because treated dams of both generations produced as many offspring as the control animals, the biological significance of these findings is unclear.

This study is supported by intermediate-duration NOAELs for hematological effects of 75 mg/kg/day in dogs (Hart 1980) and 73 mg/kg/day in mink (Bucci et al. 1994). In the Bucci et al. (1997) mink study, the next highest level, 262 or 330 mg/kg/day, produced hematological changes that included increased Heinz body counts, reticulocytes, mean cell volume, and decreased red blood cell counts.

[underlined: Dose and end point used for MRL derivation:]

[x] NOAEL [ ] LOAEL

57 mg/kg/day (490 ppm dietary concentration)

[underlined: Uncertainty Factors used in MRL derivation:]

- [X] 10 for human variability
- [X] 10 for extrapolation of from animals to humans

57 mg / kg / day ÷ 100 = 0.57 mg / kg / day

[underlined: Was a conversion used from ppm in food or water to a m&odv weight dose? If so. explain:]

The doses were calculated by the study authors.

[underlined: Other additional studies or pertinent information which lend support to this MRL:]

The critical study identified a NOAEL that was accompanied by a LOAEL. This study is supported by intermediate-duration NOAELs for hematological effects of 75 mg/kg/day in a dog study (Hart 1980) and 73 mg/kg/day in a mink study (Bucci et al. 1994). In the Hart (1980) study, beagle dogs received 0, 4, 38, or 75 mg/kg/day diisopropyl methylphosphonate in the diet for 90 days. No toxic effects, including hematological effects, were noted over the study period. In the Bucci et al. (1997) 2-generation reproductive study in mink, animals were fed 0, 16, 45, or 262 mg/kg/day (males) or 0, 20, 57, or 330 mg/kg/day (females) diisopropyl methylphosphonate for up to 12 months. While no hematological effects were found at the low- or mid-dose in either sex, high-dose males had increased Heinz body counts and high-dose females had decreased RBC counts and increased MCV, reticulocytes, and Heinz bodies. No hematological changes were found in the F_1_ kits after 11 weeks, but F_2_ high-dose male F, kits had significantly decreased RBC counts at 6 weeks of age. High-dose F_0_ females also had significant increases in absolute and relative spleen weight and spleen-to-brain weight ratio. There was a treatment-related hematopoietic cell proliferation apparent in the spleen of these animals; the spleen showed evidence of RBC replacement. The next highest level, 262 or 330 mg/kg/day in males and females, respectively, produced hematological changes that included increased Heinz body counts, reticulocytes, mean cell volume, and decreased red blood cell counts.