# 8 REFERENCES

*Cited in text

*ACGIH. 1990. Threshold limit values and biological exposure indices for 1990-1991. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Agarwal DK, Lawrence WH, Nunez LJ, . 1985. Mutagenicity evaluation of phthalic acid esters and metabolites in Salmonella typhimurium cultures. J Toxicol Environ Health 16(1):61–69.3906141
*Akiyama T, Koga M, Shinohara R, . 1980. [Detection and identification of trace organic substances in the aquatic environment.] J UOEH 2:285–300. (Japanese)
Albert LA, Delia Viveros A. 1988. [Organochlorine pesticides and phthalates in samples of rice and soil from Piedras Negras, Veracruz (Mexico).] Biotica (Mexican) 13(1–2):93–102. (Spanish)
*Albro, PW, 1989. Metabolism of di(2-ethylhexyl) phthalate. Drug Metabolism Reviews 21(1), 13–34.2696633
*Albro LA, Lavenhar SR. 1989. Metabolism of di(2-ethylhexyl)phthalate. Drug Met Rev 21(1):13–34.
*Albro PW, Moore B. 1974. Identification of the metabolites of simple phthalate diesters in rat urine. J Chromatography 94: 209–218.
Albro PW, Hass JR, Peck CC, . 1981. Identification of the metabolites of di-(Zethylhexyl) phthalate in urine from the African green monkey. Drug Metab Dispos 9:223–225.6113930
*Albro PW, Thomas R, Fishbein L. 1973. Metabolism of diethylhexyl phthalate by rats: Isolation and characterization of the urinary metabolites. J Chromatogr 76:321–330.4689606
*Al-Omran LA, Preston MR. 1987. The interactions of phthalate esters with suspended particulate material in fresh and marine waters. Environmental Pollution 46:177–186.15092728
Ames BN, McCann J, Yamasaki E. 1975. Methods for detecting carcinogens and mutagens with the Salmonellalmammalian-microsome mutagenicity test. Mutat Res 32:347–364.
*Anonymous. 1985. Final report on the safety assessment of dibutylphthalate, dimethylphthalate, and diethylphthalate. J Am Co11 Toxicol 4(3):267–303.
Ashour MB A, Moody DE, Hammock BD. 1987. Apparent induction of microsomal carboxylesterase activities in tissues of clofibrate-fed mice and rats. Toxicol Appl Pharmacol 89(3):361–369.3603566
*ATSDR. 1989. Toxicological profile for di-[Zethylhexyllphthalate. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1990. U.S. Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles. Centers for Disease Control, Public Health Service, Atlanta, GA.
*Atwater JW, Jasper SE, Parkinson PD, . 1990. Organic contaminants in Canadian coal wastewaters and associated sediments. Wat Pollut Res J Can 25(2):187–200.
*Autian J. 1973. Toxicity and health threats of phthalate esters: Review of the literature. Environ Health Perspec 4:3–26.
*Banerjee S, Howard PH, Lande SS. 1990. General structure-vapor pressure relationships for organics. Chemosphere 21:1173–1180.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis mucrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Benson WH, Stackhouse RA. 1986. Evaluation of a new approach to the safety assessment of biomaterials. Drug Chem Toxicol 9(3–4):275–284.3816615
Bernstein, Martin E. 1984. Agents affecting the male reproductive system: Effects of structure on activity. Drug Metab Rev 15:941–996.6396061
Beving HF, Petren S, Vesterberg O. 1990. Increased isotransferrin ratio and reduced erythrocyte and platelet volumes in blood from thermoplastic industry workers. Ann Occup Hyg 34(4):391–397.2240993
*Blevins RD, Taylor DE. 1982. Mutagenicity screening of twenty-five cosmetic ingredients with the Sulmonellulmicrosome test. J Environ Sci Health Part A 17:217–239.
Bodmeier R, Paeratakulo O. 1991. Determination of plasticizers commonly used in pharmaceutical dosage forms by-high liquid chromatography. Journal of Liquid Chromatography 14(2):365–375.
*Boese BL. 1984. Uptake efficiency of the gills of English sole (Parophrys vetulus) for four phthalate esters. Can J Fish Aqua Sci 41:1713–1718.
*Bouwer EJ, McCarty PL, Bouwer H, . 1984. Organic contaminant behavior during rapid infiltration of secondary wastewater at the Phoenix 23rd Ave project. Water Research 18:463–472.
*Brown D, Butterworth KR, Gaunt IF, . 1978. Short-term oral toxicity study of diethyl phthalate in the rat. Food Cosmet Toxicol 16(5):415–422.711065
*Brownlee B, Strachan WMJ. 1977. Distribution of some organic compounds in the receiving waters of a kraft pulp and paper mill. J Fish Res Board Can 34:830–837.
Bruchet A, Legrand MF, Arpino P, . 1991. Recent methods for the determination of volatile and nonvolatile organic compounds in natural and purified drinking water. J Chromatogr B Biomed Appl 562:469–480.
*Burkhard LP, Durhan EJ, Lukasewycs MT. 1991. Identification of nonpolar toxicants in effluents using toxicity-base fractionation with gas chromatography/mass spectrometry. Anal Chem 63(3):277–283.
Burmaster DE. 1982. The new pollution - groundwater contamination. Environment 24:6–13, 33–36.
*Bums BG, Musial CJ, Uthe JF. 1981. Novel cleanup method for quantitative gas chromatographic determination of trace amounts of di-2-ethylhexyl phthalate in fish lipid. J Assoc Off Anal Chem 64(2):282–286.7228824
*Cafmeyer NR, Wolfson BB. 1991. Possible leaching of diethyl phthalate into levothyroxine sodium tablets. Am J Hosp Pharm 48(N4):735–739.2042676
*Calley D, Autian J, Guess WL. 1966. Toxicology of a series of phthalate esters. J Pharm Sci 55(2):158–162.5923262
*Camanzo J, Rice CP, Jude DJ, . 1983. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments. J Great Lakes Res 13:296–309.
*Castle L, Mercer AJ, Startin JR, . 1988. Migration from plasticized films into foods: 3. Migration of phthalate, sebacate, citrate and phosphate esters from films used for retail food packaging. Food Addit Contam 5(1):9–20.3356285
Cater BR, Cook MW, Gangolli SD, . 1977. Studies on dibutylphthalate-induced testicular atrophy in the rat: Effect on zinc metabolism. Toxicol Appl Pharmacol 41:452–455.
Chambon P, Riotte M, Daudon M, . 1971. Study on the metabolism of dibutyl anddiethyl phthalate in the rat. C R Acad SC Paris 273:2165–2168.
CHEMFATE. 1985. Diethyl Phthalate. Syracuse Research Corporation, Syracuse, NY.
*Christensen D, Neergaard J, Neilsen B, . 1976. The release of plasticizers from PVC tubing. Proc Int Congr Pharmacol, 6th ed. 6: 191–197.
Cifrulak SD. 1969. Spectroscopic evidence of phthalate in soil organic matter. Soil Sci 107:63–69.
*CLPSD. 1989. Contract Laboratories Program Statistical Database. U.S. Environmental Protection Agency, Washington, DC. July, 1989.
*Cocheo V, Bellomo ML, Bombi GG. 1983. Rubber manufacture: Sampling and identification of volatile pollutants. Am Ind Hyg Assoc J 44521–527.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Davies JE. 1977. Occupational and environmental pesticide exposure study in South Florida. Natl Tech Inform Serv 370:80.
*Davies K 1990. Human exposure pathways to selected organochlorines and PCBs in Toronto and southern Ontario. Adv Environ Sci Technol 23:525–540.
*Dear WP, Jassup DC. 1978. Primary eye irritation study in the albino rabbit. Internation Research and Development Corp.
Dechesne JP, Jaminet F. 1985. Influence of some plasticizers on mechanical properties of free CAP films. J Pharm Belg 40:5–13.
*DeLeon IR, Byrne CJ, Peuler EA, . 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15(6):795–806.
*DeMarini DM, Inmon JP, Simmons JE, . 1987. Mutagenicity in Sulmonella of hazardous wastes and urine from rats fed these wastes. Mutat Res 189(3):205–216.3313035
Desai S, Govind R, Tabak H. 1990. Determination of Monod kinetics of toxic compounds by respirometry for structure-biodegradability relationships. American Chemical Society Symposium Series 422(Emerging Technologies in Hazardous Waste Management): 142–156.
*DeVault DS. 1985. Contaminants in fish from Great Lakes Harbors and Tributary Mouths. Arch Environ Contam Toxicol 14:587–594.
Dillingham EO, Autian J. 1973. Teratogenicity, mutagenicity and cellular toxicity of phthalate ester. Environ Health Perspect 3:81–89.4704573
*Dow Chemical- 1952. Results of skin irritation tests on diethyl phthalate. Midland, MI: Dow Chemical Corporation. EPA/OTS document no. 878214848.
Draize J, Alvarez E, Whitesell MF, . 1948. Toxicological investigations of compounds proposed for use as insect repellants. J Pharmacol Exp Ther 93:26–39.18865184
Eiceman GA, Clement RE, Karasek FW. 1981. Variations in concentrations of organic compounds including polychlorinated dibenzo-p-dioxins and polynuclear aromatic hydrocarbons in fly ash from a municipal incinerator. Anal Chem 53:955–959.
Ekwall B, Nordensten C, Albanus L. 1982. Toxicity of 29 plasticizers to HeLa cells in the MIT-24 system. Toxicology 24(3–4):199–210.6927640
*Elsisi AE Carter DE, Sipes IG. 1989. Dermal absorption of phthalate diesters in rats. Fundam Appl Toxicol 12(1):70–77.2925020
*EPA. 1977a. Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1977b. Toxic pollutants. U.S. Environmental Protection Agency. Federal Register 45(229): 44502–44503.
*EPA. 1978. List of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1979. Water-related environmental fate of 129 pollutants. Vol. II. Washington, DC: U.S. Environmental Protection Agency. EPA-440/4-79-029B.
*EPA. 1980a. Ambient water criteria document: Phthalate esters. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA 440/5-80-067.
*EPA. 1980b. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1980c. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Federal Register 45(229): 78530–78550.
*EPA. 1981a. Determination of phthalates in industrial and municipal waste waters. Technical report. Cincinnati, OH: U.S. Environmental Protection Agency. EPA-60014-81-063.
*EPA. 1981b. Exposure and risk assessment for phthalate esters: Di(Zethylhexy1) phthalate, di-nbutyl phthalate, dimethyl phthalate, diethyl phthalate, di-n-octyl phthalate, butyl benzyl phthalate. Final report. Washington, DC: U.S. Environmental Protection Agency. EPA-440/4-81-020.
*EPA. 1985a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1985b. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Federal Regulations. 50(65): 13474–13522.
*EPA. 1986a. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume III: Semi-volatile organic compounds. Washington, DC: U.S. Environmental Protection Agency. EPA-560/5-860-037.
*EPA. 1986b. Test methods for evaluations solid wastes: Laboratory manual-physicavchemical methods. Vol. 18. Washington, DC: U.S. Environmental Protection Agency. Method 8060: Phthalate esters, 1–14.
*EPA. 1987a. Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1987b. Ground-water monitoring list. U.S. Environmental Protection Agency. Federal Register 52(13 1): 25942–25952.
*EPA. 1987c. List of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1987d. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Federal Register 52(31):4025–4843.
*EPA. 1987e. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Federal Register 52(107):21152–21177.
*EPA. 1988a. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1988b. Hazardous constituents. U.S. Environmental Protection Agency. Federal Register 53(78): 13382–13393.
*EPA. 1988c. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.10
*EPA. 1989. Health and environmental effects profile for phthalic acid esters. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Criteria and Assessment Office. EPA/600/22.
*EPA. 1990. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*Fatoki OS, Vernon F. 1990. Phthalate esters in rivers of the greater Manchester area, England. Sci Total Environ 95:227–232.
Fawell JK, Fielding M. 1985. Identification and assessment of hazardous compounds in drinking water. Sci Total Environ 47:317–341.3911416
*FDA. 1977a. Indirect food additives: Adhesives and components of coatings. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
*FDA. 1977b. Indirect food additives: Adhesives and components of coatings. Food and Drug Administration. Federal Register 42(50): 14534–14554.
Ferrario JB, DeLeon IR, Tracy RE. 1985a. Evidence for toxic anthropogenic chemicals in human thrombogenic coronary plaques. Arch Environ Contam Toxicol 14:529–534.4051565
*Field EA, Price CJ, Sleet RB, . 1993. Developmental toxicity evaluation of diethyl and dimethyl phthalate in rats. Teratology 48:33–44.8351646
Fielding M, Packham RF. 1977. Organic compounds in drinking water and public health. J Inst Water Eng Sci 31:353–375.
*Foster P MD, Thomas LV, Cook MW, . 1980. Testicular effects and changes in zinc excretion produced by some n-alkyl phthalates in the rat. Toxicol Appl Pharmacol 54(3):392–398.7394794
*Foster P MD, Thomas LV, Cook MW, . 1983. Effect of di-n-pentyl phthalate treatment on testicular steroidogenic enzymes and cytochrome p-450 in the rat. Toxicol Lett (AMST) 15(2–3):265–272.
*Fredricsson B, Mijller L, Pousette A, . 1993. Human sperm motility is affected by plasticizers and diesel particle extracts. Pharmacol Toxicol 72: 128–133.
*FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee.
Gangolli SD. 1981. Testicular effects of phthalate esters. Conference on phthalates, Washington, DC, June 9-11. Health Perspect 45:77–84.
Gesler RM. 1973. Toxicology of di-2-ethylhexyl phthalate and other phthalic acid ester plasticizers. Environ Health Perspec 3:73–79.
*Giam CS, Chan HS. 1976. Control of blanks in the analysis of phthalates in air and ocean biota samples. Special publication. National Bureau of Standards Special Publication 422:701–708.
*Giam CS, Wang MK. 1987. Plasticizers in food. J Food Prot 50(9):769–782.
*Gibbons JA, Alexander M. 1989. Microbial degradation of sparingly soluble.organic chemicals: Phthalate esters. Environ Toxicol Chem 8(4):283–291.
*Gollamudi R, Lawrence WH, Rao RH, . 1985. Effects of phthalic acid esters on drug metabolizing enzymes of rat liver. J Appl Toxicol 5(6):368–371.3935708
*Goodley PC, Gordon M. 1976. Characterization of industrial organic compounds in water. Transactions of the Kentucky Academy of Science 37: 11–15.
*Govind R, Flaherty PA, Dobbbs RA. Fate and effects of semivolatile organic pollutants during anaerobic digestion of sludge. Water Research 25(5):547–556.
Grady CPL Jr. 1990. Biodegradation of toxic organics: Status and potential. J Environ Eng 116805–828.
*Gray TJ, Butterworth KR. 1980. Testicular atrophy produced by phthalate esters. Arch Toxicol Suppl 4:452–455.
*Grayson BT, Fosbraey LA. 1982. Determination of the vapor pressure of pesticides. Pestic Sci 13:269–278.
*Greif N. 1967. Cutaneous safety of fragrance materials as measured by the Maxinization Test. American Perfumer and Cosmetics 82:54–57.
*Grove RS Faeder EJ, Ospital J, . 1985. Halogenated compounds discharged from coastal power plant. In: Volley RL, ., eds. Water chlorination. Vol. 5: Chemistry environmental impact and health effects. Fifth Conference on water chlorination: Environmental impact and health effects, Williamsburg, VA, June 3-8, 1984. Chelsea, MI: Lewis Publishers, 1371–1380.
*Guy MG, Powers RG. 1977. Timed-release aspirin. U.S. patent no. 4025623.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Saunders Company, Harcourt Brace Jovanovich, Inc., 13–20.
*Hagen DF, Markell CG, Schmitt GA. 1990. Membrane approach to solid-phase extractions. Anal Chim Acta 236(1):157–164.
Hakuta T, Negishi A, Goto T, . 1977. Vapor-liquid equilibrium of some pollutants in aqueous and saline solutions: Part 1. Experimental results. Desalination 21:11–21.
*Hancock W, Rose BA, Singer DD. 1966. The determination of diethyl phthalate in cosmetic preparations. Analyst 91:449–454.5940074
*Hardin BD, Schuler BD, Burg RL, . 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratog Carcinog Mutagen 7:29–48.2884741
*Hattori Y, Kuge Y, Nakagawa S. 1975. Microbial decomposition of phthalate esters in environmental water. Pollut Control Cent 16:951–954.
*Haubenstricker ME, Holodnick SE, Mancy KH, . 1990. Rapid toxicity testing based on mitochondrial respiratory activity. Bull Environ Contam Toxicol 44(5):675–680.2344473
*Hawley GG. 1987. Hawley’s condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Company, Inc., 394.
*HAZDAT. 1992. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Heidel FJ, Gulati DK, Mounce RC, . 1989. Reproductive toxicity of three phthalate acid esters in a continuous breeding protocol. Fundam Appl Toxicol 12(3):508–518.
*Heindel JJ, Powell CJ. 1992. Phthalate ester effects on rat Sertoli cell function in vitro: Effects of phthalate side chain and age of animal. Toxicol Appl Pharmacol 115: 116–123.1321518
Hori R, Okumura K, Inui K, . 1977. Pharmaceutical approach to the oral dosage form of macromolecules: Effect of bile salts and oil-in-water emulsions on the intestinal absorption of urogastrone in the rat. Chem Pharm Bull 25(8):1974–1979.
*Horowitz A, Shelton DR, Cornell CP, . 1982. Anaerobic degradation of aromatic compounds in sediment and digested sludge. Dev Ind Microbial 23:435–444.
*Hotchkiss SAM, Gamett A, Hewitt P, . 1992. Percutaneous absorption of topically applied chemicals through human skin in vitro. Proceedings of the BPS, 8-10 April 1992, p 148P.
Howard PH. 1989. Handbook of environmental fate and exposure data for organic chemicals. I. Large production and priority pollutants. Chelsea, MI: Lewis Publishers, Inc., 269–279.
*Howard PH, Banerjee S, Robrillard KH. 1985. Measurement of water solubilities, octanol-water partition coefficients and vapor pressures of commercial phthalate esters. Environmental Toxicology and Chemistry 4:653–661.
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. September 11, 1994.
*Hutchins SR, Tomson MB, Ward CH. 1983, Trace organic contamination of ground water from a rapid infiltration site: A laboratory-filled coordinator study. Environmental Toxicology and Chemistry 2:195–216.
*Inouye B, Ogino Y, Ishida T, . 1978. Effects of phthalate esters on mitochondrial oxidative phosphorylation in the rat. Toxicol Appl Pharmacol 43: 189–198.24285
*IRIS. 1991. Integrated Risk Information Systems. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH.
*Ishidate M Jr, Odashima S. 1977. Chromosome tests with 134 compounds on Chinese hamster cells in vitro: A screening for chemical carcinogens. Mutat Res 48:337–354.876270
Ishihara M. 1978. The environment and the skin. Journal of the Medical Society of Toho University. ISSN 00408640. 750–765.
Jaeger RJ, Rubin RJ. 1970a. Extraction, metabolism and accumulation of phthalate plasticizers from plastic tubing during perfusion of the isolated rat liver [Abstract]. Fed Proc 29:411
Jaeger RJ, Rubin RJ. 1970b. Plasticizers form plastic devices: Extraction, metabolism and accumulation by biological systems. Science 170:460.5460077
Jaeger RJ, Rubin RJ. 1972. Migration of phthalate ester plasticizer from polyvinyl chloride blood bags into stored human blood and its localization in human tissues. New Engl J Med 287:1114–1118.5082191
*Jones HB, Garside DA, Liu R, . 1993. The influence of phthalate esters on Leydig cell structure and function in vitro and in vivo. Experimental and Molecular Pathology 58:179–193.8519345
*Jungclaus GA, Games LM, Hites RA. 1976. Identification of trace organic compounds in tire manufacturing plant wastewaters. Anal Chem 481894–1896.
*Kamrin MA, Mayor GH. 1991. Diethyl phthalate - a perspective. J Clin Pharmacol 31(5):484–489.2050836
Kaneshima H, Yamaguchi T, Okui T, . 1978. Studies on the effects of phthalate esters on the biological system: Part 2. In vitro metabolism and biliary excretion of phthalate esters in rats. Bull Environ Contam Toxicol 19(4):502–509.656651
Karasek FW. 1978. Environmental analyses by GC/MS/computer. Industrial Research/Development 113–118.
*Karegoudar TB, Pujar BG. 1984a. Biodegradation of phthalates and phthalate esters. Proc Ind Acad Sci Chem Sci 93:1155–1158.
*Karegoudar TB, Pujar BG. 1984b. Metabolism of diethyl phthalate by soil bacterium. Current Microbiology 11:321–324.
*Karegoudar TB, Pujar BG. 1985. Isolation and identification of microorganisms capable of degrading terephthalate and diethyl phthalate. Journal of the Kamatak University-Science 29:69–73.
Kasuya M. 1974. Toxicity of phthalate esters to nervous tissue in culture. Bull Environ Contam Toxicol 12(2):167–172.4474038
Keenlyside RA. 1984. Indoor air quality. In: JM Harrington, ed. Recent advances in occupational health. Churchill Livingstone, Edinburgh, 59–71.
*Keith LH, Garrison AW, Allen FR, . 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Press, 329–373.
Khan Mr, Ong CP, Li S FY, . 1990. Optimization of the isocratic high-performance liquid chromatographic separation of selected phthalates using the overlapping resolution mapping technique. J Chromatogr 513:360–366.
Kinlin TE, Muralidhara R, Pittet AO. 1972. Volatile components of roasted filberts. J Agric Food Chem 20:1021–1028.
*Klausmeier RE, Jones WA. 1960. Microbial degradation of plasticizers. Develop Ind Microbiol 2:47–53.
*Kluwe WM. 1982. Overview of phthalate ester pharmacokinetics in mammalian species. Environ Health Perspect 45:3–9.6754362
*Kopfler FC, Melton RG, Mullaney JL, . 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Kozumbo WJ. 1984. I. Dimethyl phthalate: Studies on metabolism, tissue binding and genotoxicity. II. 2(3)-tert-butyl-4-hydroxyanisole: Effects on early biochemical events associated with tumor promotion. Dissertation Abstracts International 44(11):3366-B.
*Kozumbo WJ, Kroll R, Rubin RJ. 1982. Assessment of the mutagenicity of phthalate esters. Conference on phthalates, Washington, D.C., June 9-11, 1981. Eviron Health Perspect 45(0):103–110.
Krauskopf LG. 1973. Studies on the toxicity of phthalates via ingestion. Environ Health Perspect 3:61–72.4735798
*Kurane R. 1986. Microbial degradation of phthalate esters. Microbiological Science 3:92–95.
*Kurane R, Suzuki T, Takahara Y. 1977. Microbial degradation of phthalate esters: Part 1. Isolation of microorganisms growing on phthalate esters and degradation of phthalate esters by Pseudomonas acidovorans 256-1. Agric Biol Chem 41:2119–2123.
*Laane C, Boeren S, Hilhorst R, . 1987. Optimization of biocatalysis in organic media. In: Laane C, Tramper J, Lilly MD, eds. Biocatalysis in organic media. Amsterdam, the Netherlands: Elsevier Science Publishers, 37.
*Lake BG, Phillips JC, Linnell JC, . 1977. The in vitro hydrolysis of some phthalate? diesters by hepatic and intestinal preparations from various species. Toxicol Appl Pharmacol 39(2):239–248.403636
*Lamb JC, Chapin C IV, Teague RE, . 1987. Reproductive effects of four phthalic acid esters in the mouse. Toxicol Appl Pharmacol 88:225–269.3564041
*Lawrence WH, Malik M, Turner JE, . 1975. A toxicological investigation of some acute, short-term, and chronic effects of administering di-2-ethylhexyl phthalate (DEHP) and other phthalate esters. Environ Res 9:1–11.1122902
Lederer J. 1986. [Problems raised by possible contamination foods by phthalates.] Arch Belg Med Sot 44(1–2):3–44. (French)
*Lewis DL, Holm HW. 1981. Rates of transformation of methyl parathion and diethyl phthalate by aufwuchs microorganisms. Appl Environ Microbial 42:698–703.
Lewis DL, Hall TL, Holm HW. 1981. Fate of diethyl phthalate in chemostats. 182nd American Chemical Society National Meeting, New York, N.Y., August 23-28, 1981. Abstracts of Papers: American Chemical Society, 182.
*Lewis DL, Hodson RE, Freeman LF III. 1984a. Effects of microbial community interactions on transformation rates of xenobiotic chemicals. Appl Environ Microbial 48561–565.
*Lewis DL, Holm HW, Kollig HP, . 1984b. Transport and fate of diethyl phthalate in aquatic ecosystems. Environmental Toxicology and Chemistry 3:223–232.
*Lewis DL Kellogg RB, Holm HW. 1985. Comparison of microbial transformation rate coefficient of xenobiotic chemicals between field-collected and laboratory microcosm microbiota. In: Boyle TP, ed. Validation and predictability of laboratory methods for assessing the fate and effects of contaminants in aquatic ecosystems. Philadelphia, PA: American Society for Testing and Materials. ASTM special technical publication 865 3:13.
*Leyder F, Boulanger P. 1983. Ultraviolet absorption, aqueous solubility, and octanol-water partition for several phthalates. Bull Environ Contam Toxicol 30:152–157.6839039
Ligocki MP, Levenberger C, Pankow JF. 1985. Trace organic compounds in rain - II. Gas scavenging of neutial organic compounds. Atmos Environ 19: 1609–1617.
*Lopez-Avila V, Milanes J, Beckert WF. 1991. Single-laboratory evaluation of method 8060 for the determination of phthalates in environmental samples. J. Assoc. Off. Anal. Chem. 74(5):793–808.
*Lopez-Avila, V, Milanes J, Constantine F, . 1990. Typical phthalate ester contamination incurred using EPA-method 8060. J Assoc Off Anal Chem 73(5):709–720.
*Lopez-Avila V, Milanes J, Dodhiwala NS, . 1989. Cleanup of environmental sample extracts using florisil solid-phase extraction cartridges. J Chromatogr Sci 27(5):209–220.2745661
Mabey WR, Smith JH, Pod011 RT, . 1981. Aquatic fate process data for organic pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA-440/4-81-014.
*McFall JA, Antoine SR, DeLeon IR. 1985a. Base-neutral extractable organic pollutants in biota and sediments from Lake Pontchartrain. Chemosphere 14(10):1561–1569.
*McFall JA Antoine SR, DeLeon IR. 1985b. Organics in the water column of Lake Pontchartrain New-Orleans, Louisiana, USA. Chemosphere 14(9):1253–1266.
Melnick RL, Schiller CM. 1982. Mitochondrial toxicity of phthalate esters. Environ Health Perspect 45:51–56.7140696
Milkov LE, Aldyreva MV, Popova TB, . 1973. Health status of workers exposed to phthalate plasticizers in the manufacture of artificial leather and films based on PVC resins. Environ Health Perspect 3:175–178.4704567
*Monsanto Corporation. 1983. Biodegradability of Plasticizers and Related Compounds. OTS fiche number 0206236, Document number 878211024.
*Moody DE, Reddy JK. 1978. Hepatic peroxisome (microbody) proliferation in rats fed plasticizers and related compounds. Toxicol Appl Pharmacol 45(2):497–504.705785
Morrissey RE, Lamb JC IV, Morris RW, . 1989. Results and evaluations of 48 continuous breeding reproduction studies conducted in mice. Fundam Appl Toxicol 13(4):747–777.2620795
Murature DA, Tang SY, Steinhardt G, . 1987. Phthalate esters and semen quality parameters. Biomed Environ Mass Spectrom 14(8):473–478.2957007
*Murray HE, Ray LD, Giam CS. 1981. Analysis of marine sediment, water and biota for selected organic pollutants. Chemosphere 10: 1327–1334.
Nakayama S, Kawabe Y, Ishiguro T, . 1979. [Evaluation of GC-MS analysis for the identification of chemicals in fish: 3.1 Nippon Kankyo Eisei Senta Shoho 6:82–88. (Japanese)
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. Data base report on state, local, and EPA air toxics activities. National Air Toxics Information Clearinghouse. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. August 13, 1991.
Neergaard J, Nielsen B, Faurby V, . 1975. On the exudation of plasticizers from PVC hemodialysis tubjngs.. Nephron 14(3–4):263–274.1128752
Nikonorow M, Mazure H, Piekacz H. 1973. Effect of orally administered plasticizers and polyvinyl chloride stabilizers in the rat. Toxicol Appl Pharmacol 26:253–259.4751104
*NIOSH. 1992. NIOSH recommendation for occupational safety and health. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. Compendium of policy documents and statements, 92–100.
*NOES. 1990. National Occupational Exposure Survey (1981-1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
Norback D, Rand G, Michel I, . 1989. The prevalence of symptoms associated with sick buildings and polluted industrial environments as compared to unexposed reference groups without expressed dissatisfaction. Environ Int 15(1–6):85–94.
*NREPC. 1988. Kentucky waste management regulations. Frankfort, KY: Department for Environmental Protection, Natural Resources and Environmental Protection Cabinet. 401 KAR 31:040.
*NTP. 1984. Diethyl phthalate: Reproduction and fertility assessment in CD-l mice when administered in the feed. Research Triangle Park, NC: National Toxicology Program. NTP-84-262.
*NTP. 1993. NTP technical report on the toxicology and carcinogenesis studies of diethylphthalate (CAS No. 84-66-2) in F344/N rats and B6C3F, mice (dermal studies) with dermal initiation/promotion study of diethylphthalate and dimethylphthalate (CAS No. 131-1 l-3) in male Swiss (CD-l) mice.
NTP TR 429. U.S. Department of Health and Human Services, National Institutes of Health, Research Triangle Park, NC.
*O’Conner OA, Rivera MD, Young LY. 1989. Toxicity and biodegradation of phthalic acid esters under methanogenic conditions. Environ Toxicol Chem 8:569–576.
*O’Grady DP, Howard PH, Werner AF. 1985. Activated sludge biodegradation of 12 commercial phthalate esters. Appl Environ Microbial 49(2):443–445.
*OHM/TADS. 1991. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc.
Ohyama T. 1976. Effects of phthalate esters on the respiration of rat liver mitochondria. J Biochem 79:153–158.181366
*Oishi S, Hiraga K. 1980. Testicular atrophy induced by phthalic acid esters: Effect on testosterone and zinc concentrations. Toxicol Appl Pharmacol 53(1):35–41.7385236
Olsen PR, Larsen NA, Faurby V, . 1982. Nephrotoxicity of plasticizers investigated by 48 hours hypothermic perfusion of dog kidneys. Stand J Urol Nephrol 16(2):187–90.
*OSHA. 1987. Access to employee exposure and medical records. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20.
*OSHA. 1988. Access to employee exposure and medical records. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 53:30163–30164.
*OSHA. 1989a. Toxic and hazardous substances. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1989b. Toxic and hazardous substances. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 54:2920–2960.
Pankow JF, Ligocki MP, Rozen ME, . 1988. Adsorption-thermal desorption with small cartridges for the determination of trace aqueous semivolatile organic compounds. Anal Chem 60(1):40–47.
*Parker LV, Jenkins TF. 1986. Removal of trace-level organics by slow-rate land treatment. Water Research 20(11): 1417–1426.
Parker LV, Jenkins TF, Foley BT. 1984. Impact of slow-rate land treatment on groundwater quality: Toxic organics. U.S. Army Cold Regions Research and Engineering Laboratory. CRREL report 84-30 ADA 153253.
*Payne WR Jr, Benner JE. 1981. Liquid- and gas-chromatographic analysis of diethyl phthalate in water and sediment. J Assoc Off Anal Chem 64(6):1403–1407.
*Peakall DB. 1975. Phthalate esters: Occurrence and biological effects. Residue Rev 54:1–41.1093245
*Peterson JC, Freeman DH. 1982a. Method validation of gas chromatography-mass spectrometry-selected ion monitoring analysis of phthalate esters in sediment. Int J Environ Anal Chem 12(3–4):277–292.
Peterson JC, Freeman DH. 1982b. Phthalate ester concentration variations in dated sediment cores from the Chesapeake Bay. Environ Sci Technol 16:464–469.
*Peterson JC, Freeman DH. 1984. Variations of phthalate ester concentrations in sediments from the Chester River, Maryland. Int J Environ Anal Chem 18(4):237–252.6526565
Petrasek AC, Kugelman IJ, Austem BM. 1983. Fate of toxic organic compounds in wastewater treatment plants. J Water Pollut Control Fed 55:1286–1296.
*Pierce RC, Mathur SP, Williams DT, . 1980. Phthalate esters in the aquatic environment. Ottowa, Canada: National Research Council of Canada, Associate Committee on Scientific Criteria for Environmental Quality Pub1 (17583): 1–108.
*Pollack M, Li RC, Ermer JC, . 1985. Effects of route of administration and repetitive dosing on the disposition kinetics of di(Zethylhexy1) phthalate and its mono-de-esterified metabolite in rats. Tox Appl Pharm 79:246–256.
Potapov AA, Vladimirova VV, Sazonova ZV, . 1973. [Comparative tests of dimethyl phthalate, diethyl phthalate, and dibutyl phthalate as repellents.] Med Parazitol, Parazit Bolez 42(6):692–697. (Russian)
Potin-Gautier M, Bonastre J, Grenier P. 1980. A new method for anaiysis of organic micropollutants in water: Vapor pressure measurement. Environ Technol Lett 1(10):464–473.
*Preston MR, Al-Omran LA. 1989. Phthalate ester speciation in estuarine water, suspended particulates and sediments. Environmental Pollution 62(2–3):183–194.15092344
Price CJ, Sleet RB, George JD, . 1989. Developmental toxicity evaluation of diethyl phthalate in CD rats [Abstract]. Teratology 39(5):473–474.
Purvis SF, Shedroff AH, Van Der Sluis D, . 1987. Significance of non-genotoxicity in the prediction of carcinogenic risk to humans. Eighteenth Annual Meeting of the Environmental Mutagen Society, San Francisco, CA, April 8-12, 1987. Environ Mutagen 9(Supp 8):86–87.
*Ray LE, Giam CS. 1984. Organic pollutants in Texas USA coastal waters. 2nd International Symposium on responses of marine organism to pollutants, Woods Hole, Mass., April 27-29, 1983. Marine Environmental Research 14(1–4):513–514.
Reich RA, O’Hagen KA. 1990. Chemicals and allied products. Res J Water Pollut Control Fed 62(4):499–507.
*Ritsema R, Cofino WP, Frintop PCM, . 1989. Trace-level analysis of phthalate esters in surface water and suspended particulate matter by means of capillary gas chromatography with electron-capture and mass-selective detection. Chemosphere 18:2161–2175.
Roed-Petersen J, Clemmensen OJ, Menne T, . 1988. Purpuric contact dermatitis from black rubber chemicals. Contact Dermatitis 18(3): 166–168.3365970
Rowe RC, Kotaras AD, White EFT. 1984. Evaluation of the plasticizing efficiency of the dialkyl phthalates in ethylcellulose films using the torsional braid pendulum. Int J Pharm 22:57–62.
RTECS. 1991. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC. February 19, 1991.
Rubin RJ, Kozumbo W, Kroll R. 1979. Ames mutagenic assay of a series of phthalic acid esters: Positive response of the dimethyl and diethyl esters in TAlOO. Toxicol Appl Pharmacol 48:A133.
*Russell DJ, McDuffie B. 1983. Analysis for phthalate esters in environmental samples: Separation from polychlorinated biphenyls and pesticides using dual column liquid chromatography. Int J Environ Anal Chem.15(3):165–184.
*Russell DJ, McDuffie B. 1986. Chemodynamic properties of phthalate esters partitioning and soil migration. Chemosphere 15(8):1003–1022.
*Russell DJ, McDuffie B, Fineberg S. 1985. The effect of biodegradation on the determination of some chemodynamic properties of phthalate esters. J Environ Sci Health A 20:927–941.
Safwat SM, Hafez E, El-Monem HA, . 1989. Polymeric films as topical drug delivery systems for antibiotics and local anesthetics. Bull Pharm Sci Assuit Univ 12(1):152–172.
Sato H, Sato N, Ichihara N, . 1975. [Ret-assay application for mutagenicity testing of phthalate esters.] Rep Hokkaido Inst Public Health (Hoklcaido-Ritsu Eisei Kenkyushoho) 25: 146–147. (Japanese)
*Sax NI, Lewis RJ, eds. 1989. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold, 1244.
Schulsinger C, Mullgaard K. 1980. Polyvinyl chloride dermatitis not caused by phthalates. Contact Dermatitis 6(7):477–480.7214892
Schwartz BS, Ford DP, Bolla KI, . 1990. Solvent-associated decrements in olfactory function in paint manufacturing workers. Am J Ind Med 18(6):697–706.2264568
*Scott RC, Dugard PH, Ramsey JD, . 1987. In vitro absorption of some o-phthalate diesters through human and rat skin. Environ Health Perspect 74:223–227.3691429
*Seed JL. 1982. Mutagenic activity of phthalate esters in bacterial liquid suspension assays. Environ Health Perspect 45 : 111–114.6754360
*Shelton DR, Tiedje JM. 1984. General method for determining anaerobic biodegradation potential. Appl Environ Microbial 47:850–857.
*Shelton DR, Boyd SA, Tiedje JM. 1984. Anaerobic biodegradation of phthalic acid esters in sludge. Environ Sci Technol 18:93–97.22292682
Shibko SI, Blumenthal H. 1973. Toxicology of phthalic-acid esters in food packaging material. Environ Health Perspect 3:131–137.4704561
*Shields HC, Weschler CJ. 1987. Analysis of ambient concentrations of organic vapors with a passive sampler. J Air Pollut Control Assoc 37(9):1039–1045.
Shinohara R, Kido A, Eto S, . 1981. Identification and determination of trace organic substances in tap water by computerized gas chromatography-mass spectrometry and mass fragmentography. Water Research 15(5):535–542.
Simmons JE, DeMarini DM, Berman E. 1988. Lethality and hepatotoxicity of complex waste mixtures. Environ Res 46(1):74–85.3371293
*Singh AR, Lawrence WH, Autian J. 1971. Teratogenicity of a group of phthalate esters in rats. Wilmington, DE: E.I. DuPont DeNemours and Co., Inc. EPA/OTS document no. 878213812.
*Singh AR, Lawrence WH, Autian J. 1972. Teratogenicity of phthalate esters in rats. J Pharm Sci 61(1):51–55.5058645
*Singh AR, Lawrence WH, Autian J. 1973. Embryonic-fetal toxicity and teratogenic effects of adipic acid esters in rats. J Pharm Sci 62(10):1596–1600.4796182
*Singh AR, Lawrence WH, Autian J. 1975. Maternal-fetal transfer of 14C-di-2-ethylhexyl phthalate and 14C-diethyl phthalate in rats. J Pharm Sci 64(8):1347–1350.1151708
*Smyth HF, Smyth HF, Jr. 1931. Investigation of certain plasticizers: Report 1. Acute toxicity to small animals. Wilmington, DE: E.I. DuPont DeNemours and Co., Inc. EPA/OTS document no. 87211708.
*Smyth HF, Smyth I-IF Jr. 1932. Investigation of toxicity of certain plasticizers: Report 1. Chronic toxicity to small animals. Wilmington, DE: E.I. DuPont DeNemours and Co., Inc.
*SRI. 1991. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International. 885.
Stalling DL, Tindle RC, Johnson JL. 1972. Cleanup of pesticide and PCB residues in fish extracts by gel1 permeation chromatography. J Assoc Off Anal Chem 55:32.4125904
*Staples CA, Werner A, Hoogheem T. 1985. Assessment of priority pollutant concentrations in the United States using storet database. Environ Toxicol Chem 4:131–142.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. Second edition. Beltsville, MD: Bradford Communications Corporation, 274–275.
*Sugatt RH, O’Grady DP, Banerjee S, . 1984. Shake flask biodegradation of 14 commercial phthalate esters. Appl Environ Microbial 47:601–606.
*Swain WR. 1978. Chlorinated organic residues in fish, water, and precipitation from the vicinity of Isle Royale, Lake Superior. J Great Lakes Res 4:398–407.
*Tabak HH, Quave SA, Mashini CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Contr Fed 53: 1503–1508.
*Takeshita R, Takabatake E, Minagawa K, . 1977. Micro-determination of total phthalate esters in biological samples by gas-liquid chromatography. J Chromatogr 133(2):303–310.190247
Tanaka C, Siratori K, Ikegami K, . 1987. [A teratological evaluation following dermal application of diethyl phthalate to pregnant mice.] Oyo Yakuri 33(2):387–392. (Japanese)
Tavares IA, Bennett A, Gaffen JD, . 1984. The biological activities of phthalate esters on rat gastric muscle. Eur J Pharmacol 106(2):449–452.6597777
*Taylor BF, Curry RW, Corcoran EF. 1981. Potential for biodegradation of phthalic acid esters in marine regions. Appl Environ Microbial 42:590–595.
Teghsoonian R, Teghtsoonian M, Berglund B, . 1978. Invariance of odor strength with sniff vigor: An olfactory analogue to size constancy. J Exp Psycho [Human Percept] 4(1):144–152.
*Telliard WA. 1990. Broad-range methods for determination of pollutants in wastewater. J Chromatogr Sci 28(9):453–459.
Teranishi H, Kasuya M. 1980. Effects of phthalate esters on fibroblasts in primary culture. Toxicol Lett (AMST) 6(1):11–16.
*Thomas GH. 1973. Quantitative determination and confirmation of identify of trace amounts of dialkyl phthalates in environmental samples. Environ Health Perspect 3:23–28.4704571
Thomas JA, Wienckowski DB, Gillies BA, . 1986. Effects of phthalic acid esters (PAEs) on the neonate and aspects of teratogenic actions. Environ Health Perspect 65:243–248.3709448
*Tomson MB, Dauchy J, Hutchins S, . 1981. Groundwater contamination by trace level organics from a rapid infiltration site. Water Research 15:1109–1116.
*TRI88. 1990. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Urushigawa Y, Yonezawa Y. 1979. Chemico-biological interactions in biological purification systems. VI. Relation between biodegradation rate constants of di-n-alkyl phthalate esters and their retention times in reverse phase partition chromatography. Chemosphere 5:317–320.
*USITC. 1981. Synthetic organic chemicals: United States production and sales, 1980. Washington, DC: United States International Trade Commission. USITC publication 1183, 187–188.
*USITC. 1988. Synthetic organic chemicals: United States production and sales, 1987. Washington, DC: United States International Trade Commission. USITC publication 2118, 1l-2 to 1l-3.
*van Lierop J BH, van Veen RM. 1988. Determination of plasticizers in fat by gas chromatographymass spectrometry. J Chromatogr 447(1):230–238.
Veith GD, Austin NM. 1977. Detection and isolation of bioaccumulable chemicals in complex effluents. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor. Science, 297–302.
*Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Eaton JG, Parrish PR, Hendricks AC, eds. Aquatic toxicology. Philadelphia, PA: American Society for Testing and Materials. ASTM special technical publication 707, 116–129.
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. New York, NY: Van Nostrand Reinhold, 530–531.
Vick RD, Junk GA, Avery MJ. 1978. Organic emissions from combustion of combination coal/refuse to produce electricity. Chemosphere 7:893–902.
*Vidovic R, Kansky A. 1985. Contact dermatitis in workers processing polyvinyl chloride plastics. Dermatosen 33(3):104–105.
*Voss. 1984. Neutral organic compounds in biologically treated bleached kraft mill effluents. Environ Sci Technol 18(12):938–946.
*WAC. 1988. Control of hazardous pollutants. Wisconsin Administrative Code, Chapter NR 455. Department of Natural Resources.
*Waliszewski SM, Szymczymski GA. 1990. Determination of phthalate esters in human semen. Andrologia 22(1):69–73.2281879
*Wallace LA, Pellizzari E, Hartwell T, . 1984. Personal exposure to volatile organic compounds: I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35:293–319.6489295
*Walsh GE, Bahner LH, Homing WB. 1980. Toxicity of textile mill effluents to freshwater and estuarine algae, crustaceans and fishes. Environmental Pollution (Series A) 21: 169–179.
Watabe K, Nakanishi T, Shishido J, . 1988. Identification of some organic compounds in rain water by means of a gas chromatograph-mass spectrometer-computer system. Eisei Kagaku 34(1):25–30.
*Wolfe NL, Bums LA, Steen WC. 1980a. Use of linear free energy relationships on an evaluated model to assess the fate and transport of phthalate esters in the aquatic environment. Chemosphere 9:393–402.
*Wolfe NL, Steen WC, Bums LA. 1980b. Phthalate ester hydrolysis: Linear free relationships. Chemosphere 9:403–408.
Yoshida A, Sasaki K, Akehashi H. 1979. Degradation of phthalic acid esters by bacteria. Seikatsu Eisei 23(6):199–206.
*Zeiger E, Haworth E, Mortelmans S, . 1985. Mutagenicity testing of di(2-ethylhexyl) phthalate and related chemicals in Salmonella. Environ Mutagen 7:213–232.3971959
*Zeiger E, Haworth E, Speck S, . 1982. Phthalate ester testing in the National Toxicology Program’s environmental mutagenesis test development program. Environ Health Perspect 45:99–101.6754365
*Zhang G, Reardon KF. 1990. Parametric study of diethyl phthalate biodegradation. Biotechnol Lett 12:699–704.
*Ziogou K, Kirk PWW, Lester JN. 1989. Behavior of phthalic acid esters during batch anaerobic digestion of sludge. Water Research 23:743–748.
*Zurmiihl T. 1990. Development of a method for the determination of phthalate esters in sewage sludge including chromatographic separation from polychlorinated biphenyls, pesticides and polyaromatic hydrocarbons. Analyst (London) 115(9):1171–1175.