# 7 REGULATIONS AND ADVISORIES

The national and state regulations and guidelines regarding diethyl phthalate in air, water, and other media are summarized in Table 7-1. No international regulations or guidelines were located.

ATSDR has not derived an MRL for diethyl phthalate. EPA (IRIS 1994) assigned diethyl phthalate a reference dose (RfD) of 80x10^-1^ mg/kg/day with an uncertainty factor of 1,000 based on decreased growth rate, food consumption, and altered organ weights (Brown et al. 1978). EPA (IRIS 1994) has assigned diethyl phthalate a weight-of-evidence carcinogenic classification of D, which indicates that diethyl phthalate is not classifiable as to human carcinogenicity. Diethyl phthalate is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Right-to-Know Act of 1986” (EPA 1987e, 1988c). Diethyl phthalate is designated as a hazardous substance (EPA 1978, 1987d) and is subject to groundwater monitoring requirements (EPA 1987a, 1987b).

TABLE 7-1 Regulations and Guidelines Applicable to Diethyl Phthalate

Agency | Description | Information | References
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA-skin designation | 5.0 mg/m^3^ | OSHA 1989a (29 CFR 1910.1000); OSHA 1989b
OSHA | Meets criteria for medical records | Yes | OSHA 1987 (29 CFR 1910.20); OSHA 1988
b. Water:
EPA ODW | Designated a toxic pollutant under section 307(a)(1) of the Federal Clean Water Act and subject to effluent guidelines | Yes | EPA 1977a (40 CFR 401.15); EPA 1977b
c. Food:
FDA | Indirect food additive for use only as a component of adhesives | Yes | FDA 1977b (21 CFR 175.105); FDA 1977a
d. Other:
EPA OERR | Reportable quantity | 1,000 pounds | EPA 1985a (40 CFR 302.4); EPA 1985b
EPA OSW | Designated as a hazardous substance | Yes | EPA 1978 (40 CFR 116.4); EPA 1987d
EPA OSW | Listing as a hazardous waste: Discarded commercial chemical product off-specification species, container residues, and spill residues thereof | Yes | EPA 1980b (40 CFR 261.33); EPA 1980c
EPA OSW | Listing as a hazardous constituent | Yes | EPA 1988a (40 CFR 261, Appendix VIII); EPA 1988b
EPA OSW | Groundwater monitoring requirement | Yes | EPA 1987a (40 CFR 264, Appendix IX); EPA 1987b
EPA OTS | Toxic chemical release reporting: Community Right-to-Know | | EPA 1988c (40 CFR 372); EPA 1987e
Guidelines:
a. Air:
ACGIH | TLV TWA | 5.0 mg/m^3^ | ACGIH 1990
NIOSH | REL TWA | 5.0 mg/m^3^ | NIOSH 1992
b. Water: | Ambient water quality criteria for protection of human health: | | EPA 1980a
| Ingestion of water and organisms | 350 mg/L
| Ingestion of organism only | 1.8 g/L
c. Other:
| RfD (oral) | 8.0×10^−1^ mg/kg/day | IRIS 1990
| Carcinogenic classification | D^a^
| Unit risk (air) | No data
| Unit risk (water) | No data
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Acceptable Ambient Air Concentrations | | NATICH 1991
California-Montana | | 0.00
Connecticut | (8 hours) | 5.0×10^−1^ μg/m^3^
Florida-Ft. Lauderdale | (8 hours) | 5.0×10^−2^ mg/m^3^
Florida-Tampa | (8 hours) | 5.0×10^−2^ mg/m^3^
Florida-Pinellas | (8 hours) | 5.0×10^−1^ μg/m^3^
Florida-Pinellas | (24 hours) | 1.20×10^−1^ μg/m^3^
Florida-Pinellas | (Annual) | 8.00×10^2^ μg/m^3^
Maine | | 0.00
Maryland | | 0.00
Nevada | (8 hours) | 1.19×10^−1^ mg/m^3^
New York | (1 year) | 1.67×10^−1^ μg/m^3^
North Dakota | (8 hours) | 5.00×10^−2^ mg/m^3^
Wisconsin | Hazardous air contaminants with acceptable ambient air concentrations | Yes | WAC 1988
b. Water:
Kansas | Drinking water quality guidelines and standards | 350 mg/L | FSTRAC 1988
c. Other:
Kentucky | Defined as a hazardous waste | Yes | NREPC 1988 (401 KAR 31:040)

a D= Not classifiable as to human carcinogenicity

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; NIOSH = National Institute for Occupational Safety and Health; ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OTS = Office of Toxic Substances; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; RfD = Reference Dose; TLV = Threshold Limit Value; TWA = Time-Weighted