# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of diethyl phthalate is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of diethyl phthalate is located in Table 3-2.

TABLE 3-1 Chemical Identity of Diethyl Phthalate

Characteristic | Information | Reference
Chemical name | Diethyl phthalate | HSDB 1994
Synonym(s) | 1,2-Benzenedicarboxylic acid diethyl ester; diethyl o-phthalate; ethyl phthalate; o-benzenedicarboxylic acid diethyl ester; diethyl ester phthalic acid; phthalol; DEP; diethyl-o-phenylenediacetate | EPA 1989; HSDB 1994; OHM/TADS 1991
Registered trade name(s) | Neantine; Palatinol A; Phthalol; Placidol E; Solvanol; Unimoll DA; Anozol; Estol 1550 | HSDB 1994
Chemical formula | C_12_H_14_O_4_ | HSDB 1994
Chemical structure | [image]
Identification numbers:
CAS registry | 84-66-2 | HSDB 1994
NIOSH RTECS | TI1050000 | HSDB 1994
EPA hazardous waste | UO88 | HSDB 1994
OHM/TADS | 7217236 | HSDB 1994
DOT/UN/NA/IMCO shipping | No data
HSDB | 926 | HSDB 1994
NCI | NCI-C60048 | HSDB-1994

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/ Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Diethyl Phthalate

Characteristic | Information | Reference
Molecular weight | 222.23 | Anonymous 1988; Autian 1973
Color | Colorless | HSDB 1994
Physical state | Liquid | HSDB 1994
Melting point | −40.5°C | HSDB 1994
Boiling point | 295-302°C | Autian 1973; Banerjee et al. 1990; EPA 1989; HSDB 1990; OHM/TADS 1991; Sax and Lewis 1989
Density
at 25°C | 1.120 g/mL | Anonymous 1985
Odor | Slight aromatic odor | HSDB 1994
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25°C | 1,080 mg/L | Howard et al. 1985; HSDB 1994
Organic solvent(s) | Alcohol, ether, acetone, and benzene; vegetable oils; ketones, esters, aromatic hydrocarbons, and aliphatic solvents | HSDB 1994
Partition coefficients:
Log K_ow_ | 1.4–3.3 | Callahan et al. 1979; Howard et al. 1985: HSDB 1994 Laane et al. 1987; Leyder and Boulanger 1983; Veith et al. 1980
Log K_oc_ | 2.65 | Wolfe et al. 1980b
Vapor pressure:
at 20°C | 3.45×10^−4^ mmHg | Grayson and Fosbraey 1982
at 25°C | 1.65×10^−3^ mmHg | Howard et al. 1985; HSDB 1994
Henry’s law constant^a^ | 7.8×10^7^ atm m^3^/mol | EPA 1989
Autoignition temperature | 457°C | HSDB 1994
Flashpoint | 161°C | HSDB 1994
Flammability limits^b^ | 0.7% at 187°C | HSDB 1994
Conversion factors | 9.07 mg/m^3^ = 1 ppm | HSDB 1994
Explosive limits | No data

a Temperature not specified

a Lower flammability limit given; upper limit not available