# 8 REFERENCES

*Cited in text

*Abdi YA, Villen T. 1991. Pharmacokinetics of metrifonate and its rearrangement product dichlorvos in whole blood. Pharrnacol Toxicol 68(2): 137–139.
*ACGIH. 1994. 1994-1995 Threshold Limit Values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
“Aguera A, Contreras M, Femandez-Alba AR. 1993. Gas chromatographic analysis of organophosphorus pesticides of horticultural concern. J Chromatogr A 655(2):293–300.
*Ali SF, Chandra O, Hasan M. 1980. Effects of an organophosphate (dichlorvos) on open field behavior and locomotor activity: correlation with regional brain monoamine levels. Psychopharmacology (Berl) 68(1):37–42.6771797
*Ali SF, Hasan M, Tariq M. 1979. Levels of dopamine, norepinephrine & 5-hydroxytryptamine in different regions of rat brain & spinal cord following chronic administration of organophosphate pesticide dichlorvos. Indian J Exp Biol 17(4):424–426.489076
*AMUAC Chemical Corp. 1990. A 52-week chronic toxicity study on DDUP in dogs. Unpublished report dated August 6, 1990 submitted by AMUAC Chemical Corp. Los Angeles CA.
*Andersen ME, Clewell HJ, III, Gargas ML, . 1987. Physiologically based phartnacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87: 185–205.3824380
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. Current concepts and approaches on animal test alternatives. H. Salem, ed. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*AOAC. 1990. DDVP in pesticide formulations. Infrared spectrophotometric method. Method 1.964.04. In: Official methods of analysis of the Association of Official Analytical Chemists. K. Helrich, ed. 15th edition. Association of Official Analytical Chemists, Inc., Arlington, VA. 199.
*Aquilina G, Benigni R, Bignami M. . 1984. Genotoxic activity of dichlorvos, trichlorfon, and dichloroacetaldehyde. Pestic Sci 15:439–442.
*Askew J, Ruzicka JHA, Wheals BB. 1969. Determination of organophosphorus pesticide residues in river waters and effluents by gas, thin-layer, and gel chromatography. Analyst (London) 94(11):275–283.5778090
*ASTER. 1996. ASTER Ecotoxicology Profile: Phosphoric acid, 2,2-Dichloroethenyl dimethyl ester (Dichlorvos). Duluth, MN: U.S. EPA Environmental Research Laboratory.
*ASTM. 1994. Method D5475-93. Nitrogen and Phosphorus containing pesticides in water by gas chromatography with a nitrogen phosphorus detector. Annual book of ASTM standards. Philadelphia, PA: American Society for Testing and Materials.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Barnabas IJ, Dean JR, Hitchen SM, . 1994. Selective extraction of organochlorine and organophosphorus pesticides using a combined solid phase extraction-supercritical fluid extraction approach. Anal Chim Acta 291(3):261–267.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Benford DJ, Price SC, Lawrence JN. 1994. Investigations of the genotoxicity and cell proliferative activity of dichlorvos in mouse forestomach. Toxicology 92: 1203–1205.
*Berteau PE, Knaak JB, Mengle DC, . 1989. Insecticide Absorption from Indoor Surfaces: Hazard Assessment and Regulatory Requirements. In: Biological Monitoring for Pesticide Exposure: Measurement, Estimation and Risk Assessment, R.G.M. Wang, ed. American Chemical Society, Washington, DC. 315–326.
*Blair D, Dix KM, Hunt PF, . 1976. Dichlorvos - a 2-year inhalation carcinogenesis study in rats. Arch Toxicol 35(4):281–294.989297
*Blair D, Hoadley C, Hutson DH. 1975. The distribution of dichlorvos in the tissues of mammals after its inhalation or intravenous administration. J Toxicol Appl Pharmacol 31(2):243–253.
*Bowman BT, Sans WW. 1983. Determination of octanol-water partitioning coefficients KOW61 organophosphorus and carbamate insecticides and their relationship to respective water solubility (S) values. J Environ Sci Health [B] 13:667–633.
*Bayer AC, Brown LJ, Slornka MB, . 1977. Inhibition of human plasma cholinesterase by ingested dichlorvos: effect of formulation vehicle. J Toxicol Appl Pharmacol 41(2):389–394.
*Braun R, Schoeneich J, Weissflog L, . 1982. Activity of organophosphorus insecticides in bacterial tests for mutagenicity and DNA repair. Direct alkylation vs. Metabolic activation and breakdown. 1. Butonate, vinyl butonate, trichlorfon, dichlorvos, demethyl dichlorvos, and demethyl vinyl butonate. Chem-Biol Interact 39(3):339–350.7074710
*Brouwer DH, Ravensberg JC, De Kort WL, . 1994. A personal sampler for inhalable mixed-phase aerosols: Modification to an existing sampler and validation test with three pesticides. Chemosphere 28(6):1135–1146.
*Bryant RJ, Minett W. 1978. A gas-chromatographic method for the determination of dichlorvos in air. Pestic Sci 9(6):525–528.
*Carere A, Cardamone G, Ortali V, . 1976. Mutational studies with some pesticides in Streptomyces coelicolor and Salmonella typhimurium. Mutat Res 38(2):136.
*Carere A, Ortali VA, Cardamone G, . 1978. Microbiological mutagenicity studies of pesticides in vitro. Mutat Res 57(3):277–286.353549
*Caroldi S, Lotti M. 1981. Delayed neurotoxicity caused by a single massive dose of dichlorvos to adult hens. Toxicol Letters 9: 157–159.
*Casale G P, Cohen S D, Dicapua R A. 1983. The effects of organophosphate induced cholinergic stimulation on the antibody response to sheep erythrocytes in inbred Mice. J Toxicol Appl Pharmacol 68(2): 198–205.
*Casale GP, Vennerstrom JL, Bavari S, . 1993. Inhibition of interleukin 2 driven proliferation of mouse CTLL2 cells, by selected carbamate and organophosphate insecticides and congeners of carbaryl. Immunopharmacol Immunotoxicol 15(2-3): 199–215.8349949
*Casida JE, McBride L, Neidermeier RP. 1962. Metabolism of 2,2-dichlorovinyl dimethyl phosphate in relation to residues in milk and mammalian tissue. J Agric Food Chem 10:370–377.
*CELDs. 1994. Computer-assisted Environmental Legislative Database. University of Illinois at Urbana.
*Given M, Brown CB, Morin RJ. 1977. Effects of organophosphate insecticides on adrenal cholesterylester and steroid metabolism. Biochem Pharmacol 26(20):1901–1907.71898
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations using physiologically-based pharmacokinetic modeling. Toxicol Ind Health 1: 111–131.3843496
*Coppock RW, Mostrom MS, Khan AA. 1984. A review of nonpesticide phosphate ester-induced neurotoxicity in cattle. Vet Human Toxicol 37(6):576–579.
*Cremlyn. 1978. Pesticides-Preparation and mode of Action. J. Wiley and Sons, LTD. 72
*Crisp S, Tarrant KR. 1971. The determination of residues of dichlorvos and malathion in wheat grain by gas-liquid chromatography. Analyst 96(141):310–313.5550767
*Cusack R, Johnson G. 1990. A study of dichlorvos (Nuvan; 2,2-dichloroethenyl dimethyl phosphate), a therapeutic agent for the treatment of salmonids infected with sea lice (Lepeophtheirus salmonis). Aquaculture 90:101–112.
*Das YT, Taskar PK, Brown HD, . 1983. Exposure of professional pest control operator to dichlorvos (DDVP) and residue on house structures. Toxicol Lett 17(1-2):95–99.6623514
*Dean BJ, Blair D. 1976. Dominant lethal assay in female mice after oral dosing with dichlorvos or exposure to atmospheres containing dichlorvos. Mutat Res 40(1):67–72.1250254
*Dean BJ, Thorpe E. 1972. Studies with dichlorvos vapor in dominant lethal mutation tests on mice. Arch Toxicol 30(1):51–59.
*Deer HM, Beck ED, Roe AH. 1993. Respiratory Exposure of Museum Personnel to Dichlorvos Insecticide. Vet Hum Toxicol 35(3):226–228.8351794
*Degraeve N, Chollet MC, Moutschen J, . 1972. Mutagenicity and interaction of chemicals in human gastric juice. Mut Res 97:179.
*Degraeve N, Chollet MC, Moutschen J, . 1982. Genetic and cytogenetic effects of chronic treatments with organophosphorus insecticides. Mutat. Res. 97:179–180.
*Desi I, Varga L, Farkas I. 1978. Studies on the immunosuppressive effect of organochlorine and organophosphoric pesticides in subacute experiments. J Hyg Epidemiol Microbial Immunol 22(1): 115–122.
*Di Corcia A, Samperi R, Marcomini A, . 1993. Graphitized carbon black extraction cartridges for monitoring polar pesticides in water. Anal Chem 65(7):907–912.
*Dieter MP, Jameson CW, French JE, . 1989. Development and validation of a cellular transplant model for leukemia in Fischer rats: a short-term assay for potential anti-leukemic chemicals. Leuk Res 13(9):841–849.2796389
*Domine D, Devilliers J, Chastrette M, . 1992. Multivariate structure-property relationships (MSPR) of pesticides. J Pestic Sci 35:73–82.
*DOT. 1989. Department of Transportation. Code of Federal Regulations. 40 CFR 302.4.
*Durham, WF, Gaines TB, Hayes WJ. 1956. Paralytic and related effects of certain organic phosphorus compounds. Arch Ind Health 13:326–330.
*Durham WF, Gaines TB, McCauley RH, . 1957. Studies on the toxicity of O,O-dimethyl-2,2-dichlorovinyl phosphate (DDVP). AMA Arch Ind Health 15:340–349.13410153
*Dzwonkowska A, Hubner H. 1986. Induction of chromosomal aberrations in the Syrian hamster by insecticides tested in vivo. Arch Toxicol 58(3):152–156.3964078
*Ecobichon DJ. 1991. Toxic effects of pesticides. In: Amdur MO, Doull J, Klaassen DC, eds. Casarett and Doull’s Toxicology: The basic science of poisons 4th ed. New York, NY: McGraw-Hill, Inc. 565–622.
*Ehrich M, Jortner BS, Padilla S. 1995. Comparison of the relative inhibition of acetylcholinesterase and neuropathy target esterase in rats and hens given cholinesterase inhibitors. Fund Appl Toxicol 24(1):94–101.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the great lakes ecosystem. Environmental Science & Technology. 30–38.
*Elgar KE, Steer BD. 1972. Dichlorvos Concentrations in the Air of Houses Arising from the Use of Dichlorvos PVC Strips. Pestic Sci 3:591–600.
*Ellinger C. 1985. Enzyme activities after in vitro and in vivo application of dichlorvos. Biomed Biochim Acta 44(2):311–316.4004835
*Ellman GL, Courtney KD, Andres V, . 1961. A new and rapid calorimetric determination of acetylcholinesterase activity. Biochem Pharmacol 7:88–95.13726518
*EPA. 1976. Investigation of Selected Potential Environmental Contaminants. Haloalkyl Phosphates. Environmental Protection Agency, Springfield, VA. NTIS No. PB257-910. 55–56.
*EPA. 1978. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1983. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122 App. D.
*EPA. 1984. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125 Instructions Form 2c.
*EPA. 1986. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1987a. Guidance for the registration of pesticide products containing DDVP as the active ingredient. Office of pesticides and toxic substances, U.S. Environmental Protection Agency (540/RE-88-016).
*EPA. 1987b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355 App. A.
*EPA. 1988a. Dichlorvos: Initiation of Special Review. Federal Register 53:5542–5549 [EPA Notice OPP-30000/56; FRL-3332-71.
*EPA. 1988b. Dichlorvos: Notice of initiation of special review. U.S. Environmental Protection Agency.Federal Register. Part IV, 53:5542–5549.
*EPA. 1988∼. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988d. Method TOlO. Compendium of methods for the determination of toxic organic compounds in ambient air. Quality Assurance Division. Environmental Monitoring Systems Laboratory Office of Research and Development. U. S. Environmental Protection Agency. Research Triangle Park, North Carolina.
*EPA. 1989. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1990a. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1990b. pesticide fact handbook, Vol 2. U.S. Environmental protection Agency. Noyes Data Corporation. 203–212.
*EPA. 1991a. Dichlorvos: Revocation of tolerance and food additive regulations: proposed rule. U.S. Environmental Protection Agency. Federal Register. 56 FR 5788-5789.
*EPA. 1991b. Method 507. Determination of nitrogen- and phosphorus-containing pesticides in water by gas chromatography with a nitrogen-phosphorus detector. Revision 2.0. In: Methods for the determination of organic compounds in drinking water. Environmental Monitoring Systems Laboratory, U.S. Environmental Protection Agency, Cincinnati, OH.
*EPA. 1992a. Method 622. The determination of organophosphorus pesticides in municipal and industrial wastewater. In: Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. EPA 821 RR-92-002. Office of Water, U.S. Environmental Protection Agency, Washington DC.
*EPA. 1992b. Method 8141A. Organophosphorus compounds by gas chromatography: capillary column technique. In: Test methods for evaluating solid waste. Vol lB, Laboratory manual, Physical/chemical methods. SW846. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, Washington DC, 4th ed.
*EPA. 1993a. Cancellation of Pesticides for Non-Payment of Registration Maintenance Fees; Notice. U.S. Environmental Protection Agency. Federal Register. 58 FR 44828.
*EPA. 1993b. Dichlorvos; Revocation of Food Additive Tolerance; Final Rule. U.S. Environmental Protection Agency. Federal Register. 58 FR 59663.
*EPA. 1993∼. U.S. Environmental Protection Agency. Federal Register. 59 FR 54836.
*EPA. 1994a. Dichlorvos; Stay of Effective Date for order revoking Food Additive Regulation; Final Rule Stay of Effective Date. U.S. Environmental Protection Agency. Federal Register. 59 FR 11556.
*EPA. 1994b. U.S. Environmental Protection Agency. Federal Register. 59 FR 15504.
*EPA. 1995a. Toxic chemical release inventory reporting form R and instructions. U. S. Environmental Protection Agency. 745-K-95-051.
*EPA. 1995b. U. S. Environmental Protection Agency. Federal Register. 60 FR 19580. April 19, 1995.
*EPA. 1995c. U. S. Environmental Protection Agency. Federal Register. 60 FR 50338. September 28, 1995.
*EPA PIN. 1994. Pesticide Monitoring Information (PMI) Facility: Project Summary of the EPA National Pesticide Survey of Drinking Water Wells. Washington, DC: EPA OPP Pesticide Information Network (PIN) On-line BBS.
*Epstein SS, Arnold E, Andrea J, . 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
*Emey DR. 1995. Determination of organophosphorus pesticides in whole-chocolate-skim-milk and infant formula using solid-phase extraction with capillary gas chromatography-flame photometric detection. HRC Journal of High Resolution Chromatography 18(1):59–62.
*Farm Chemical Handbook. 1984. Farm Chemical Handbook: Pesticide Dictionary. Meister Publishing Company, Willoughby, OH. C70–C71.
*Farm Chemical Handbook. 1994. Farm Chemical handbook: pesticide dictionary. Meister Publishing Company, Willoughby, OH. cl 11.
*FASE. 1996. Pesticide exports from U. S. ports, 1992-1994. Foundation for Advancement in Science and Education.
*Faust SD, Suffet IH. 1966. Recovery, separation and identification of organic pesticides from natural and potable waters. Residues Reviews 45–116.
*FDA. 1988. Food and Drug Administration Pesticide Program: Residue in Foods-1987. J Assoc Off Anal Chem Int 71(6):A156–A174.
*FDA. 1989. Food and Drug Administration Pesticide Program: Residue in foods-1988. J Assoc Off Anal Chem Int 72(5):133–152A.
*FDA. 1990. Food and Drug Administration Pesticide Program: Residue in foods-1989. J Assoc Off Anal Chem Int 73(5):127A–146A.
*FDA. 1991. Food and Drug Administration Pesticide Program: Residue Monitoring 1990. J Assoc Off Anal Chem Int 74(5):A121–A140.
*FDA. 1992. Food and Drug Administration Pesticide Program: Residue Monitoring 1991. J Assoc Off Anal Chem Int 75(5):A135–A157.
*FDA. 1993. Food and Drug Administration Pesticide Program: Residue Monitoring 1992. J Assoc Off Anal Chem Int 76(5):A127–A148.
*FDA. 1994a. Dichlorvos. Method 302. In: Pesticide analytical manual. Vol. 1: Multiresidues methods, 3rd ed. Food and Drug Administration, Public Health Service, U.S. Department of Health and Human Services.
*FDA. 1994b. Method 304. In: Pesticide analytical manual. Vol. 1: Multiresidues methods, 3rd ed. Food and Drug Administration, Public Health Service, U.S. Department of Health and Human Services.
*FDA. 1994c Residue monitoring, 1993 (8th annual FDA pesticide residue monitoring program report). Journal of AOAC International 77(5): 163A–185A.
*FDA. 1995. Food and Drug Administration Pesticide Program: Pesticide residue mbnitoring program. J Assoc Off Anal Chem Int 73(5): 127A–146A.
*Fedrip. 1994. Federal Research In Progress. November 1994.
*Fedrip. 1996. Federal Research In Progress. May 1996.
*Fitzgerald BB, Costa LG. 1993. Modulation of muscarinic receptors and acetylcholinesterase activity in lymphocytes and in brain areas following repeated organophosphate exposure in rats. Fund Appl Toxicol 20:210–216.
*Francis BM, Metcalf RL, Hansen LG. 1985. Toxicity of organophosphorus esters to laying hens after oral and dermal administration. J Environ Sci Health [B] 20(1):73–95.
*Gaines THB, Hayes WJ, Jr., Linder RE. 1966. liver metabolism of anticholinesterase compounds in live rats: relation to toxicity. Nature (London) 2098889.
*Gajewski D, Katkiewicz M. 1981. Activity of certain enzymes and histomorphological changes in subacute intoxication of rats with selected organophosphates. Acta Physiol Pol 32(5):507–520.7336985
*Gallo MA, Lawryk NJ. 1991. Organic phosphorous pesticides In: Hayes WJ, Laws ER eds, Handbook of Pesticide Toxicology 2:990–1001.
*Garcia MA, Femandez MI, Melgar JM. 1995. Contamination of honey with organophosphorus pesticides. Bulletin of Environmental Contamination and Toxicology 54(6):825–832.7647496
*Gelardi RC, Mountford MK. 1993. Infant Formulas: Evidence of the Absence of Pesticide Residues. Reg Toxicol Pharrnacol 17:181–192.
*Gianessi LP. 1986. A national Pesticide Usage Data Base. Renewable Resources Division, Resources for the future, 1616 P Street NW, Washington, DC, 20036.
*Goh KS, Edmiston S, Maddy KT, . 1986. Dissipation of Dislodgeable Foliar Residue for Chlorpyrifos and Dichlorvos Treated Lawn: Implications for Safe Reentry. Bull Environ Contam Toxicol 37:33–40.2424528
*Gold RE, Holcslaw T. 1985. Dermal and Respiratory Exposure of Applicators and Residents to Dichlorvos-Treated Residences. In: Dermal Exposure Related to Pesticide Use: Discussion of Risk Assessment, Honeycutt RC, Zweig G, Ragsdale NN, eds. American Chemical Society Washington, DC. 253–264.
*Gore RC, Hannah RW, Pattacini SC, . 1971. Pesticide Residues: Infrared and Ultraviolet Spectra of Seventy-six Pesticides. J Assoc Off Anal Chem 54(5): 1040–1081.5151664
*Green MH, Medcalf AS, Arlett CF, . 1974. DNA strand breakage caused by dichlorvos, methyl methanesulphoneate and iodoacetamide in escherichia coli and cultured Chinese hamster cells. Muta Res 24(3):365–378.
*Gupta AK, Singh J. 1974. Dichlorvos (DDVP) induced breaks in the salivary gland-chromosomes of Drosophila melanogaster. Cut-r Sci 43(20):661–662.
*Haley TJ, Farmer JH, Harmon JR, . 1975. Estimation of the LDl and extrapolation of the LDO. 1 for five organophosphate pesticides. Arch Toxicol 34(2): 103–109.
*Hanna PJ, Dyer KF. 1975. Mutagenicity of organophosphorus compounds in bacteria and Drosophila. Mutat Res 28:405–420.
*Haraguchi K. Kitamura E, Yamshita T, . 1995. Simultaneous determination of trace pesticides in urban precipitation. Atmospheric Environment 29(2):247–253.
*Hartley IC, Hart JP. 1994. Amperometric measurement of organophosphate pesticides using a screen-printed disposable sensor and biosensor based on cobalt phthalocyanine. Analytical Proceedings, 31(11):333–337.
*Hatch FF, Anderson TM, Lubet RA, . 1986. Chemical enhancement of SA7 virus transformation of hamster embryo cells: Evaluation by interlaboratory testing of diverse chemicals. Environ Mutagen 8(4):515–531.3732194
*Hayes WJ, Jr. 1963. Clinical handbook on economic poisons: emergency information for treating poisoning. Public Health Service publication no. 476. Communicable Diseases Center, Public Health Service, US Department of Health, Education, and Welfare. Atlanta, GA.
*Hayes WJ, Jr. 1982. Organic phosphorus pesticides. In: Pesticides Studied in Man. Williams & Wilkins, Baltimore, MD. 343–351.
*HazDat. 1995. Hazardous substances Database. Agency for Toxic Substance and Disease Registry (ATSDR), Atlanta, GA.
*HazDat. 1996. Hazardous substances Database. Agency for Toxic Substance and Disease Registry (ATSDR), Atlanta, GA.
*Heuser SG, Scudamore KA. 1966. A rapid method for sampling dichlorvos vapor in air. Chem Ind (London) 50:2093–2094.
*Hoey T, Horsberg TE, Wichstrom R. 1991. Inhibition of acetylcholinesterase in rainbow trout following dichlorvos treatment at different water oxygen levels. Aquaculture 95133–40.
*Holland PT. 1977. Routine methods for analysis of organophosphorus and carbamate insecticides in soil and ryegrass. Pestic Sci 8(4):354–358.
*Holland PT, McNaughton DE, Malcolm CP. 1994. Multiresidue analysis of pesticides in wines by solid-phase extraction. J Assoc Off Anal Chem Int 77(1):79–86.
*Holstege DM, Scharberg DL, Richardson ER, . 1991. Multiresidue screen for organophosphorus insecticides using gel permeation chromatography - silica gel cleanup. J Assoc Off Anal Chem 74(2):394–399.
*Horsberg TE, Hoey T. 1990. Residues of dichlorvos in Atlantic Salmon (Salmon salar) after delousing. J Agric Food Chem 38:1403–1406.
*Howard PH. 1991. Handbook of Environmental Fate and Exposure Data for Organic Chemicals. Vol. III. Lewis Publishers, Chelsea, MI. 251–258.
*Howden CW, Bimie CC, Brodie MJ. 1989. Drug Metabolism in liver disease. Pharmacol Ther 40:439–474.2646653
*HSDB. 1994. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Program. Bethesda MD. November 1994. HSN 319.
HSDB. 1996. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Program. Bethesda MD. May 1996.
*Hsu JP, Wheeler HG Jr., Camann DE, . 1988. Analytical methods for detection of nonoccupational exposure to pesticides. J Chromatogr Sci 26(4): 181–189.3379124
*Huff RA, Corcoran JJ, Anderson JK, . 1994. Chlorpyrifos oxon binds directly to muscarinic receptors and inhibits CAMP accumulation in rat striatum. J Pharmacol Exp Ther 269:329–335.7513360
*Hutson DH, Hoadley EC. 1972a. The comparative metabolism of [14C-vinyl] dichlorvos in animals and man. Arch Toxicol 30(1):9–18.
*Hutson DH, Hoadley EC. 1972b. The metabolism of [14 C-methyl] dichlorvos in the rat and the mouse. Xenobiotica 2: 107–116.4560365
*Hutson DH, Hoadley EC, Pickering BA. 1971. The metabolic fate of [vinyl-I-14C] dichlorvos in the rat after oral and inhalation exposure. Xenobiotica 1(6):593–611.5173023
*IARC. 1979. IARC monographs on the evaluation of carcinogenic risk to humans. Occupational exposure in insecticide application, and some pesticides, vol. 20. International Agency for Research on Cancer, Lyon, France.
*IARC. 1991. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans. Occupational Exposures in Insecticide Application, and Some Pesticides; Dichlorvos, Vol. 53. International Agency for Research on Cancer, UN World Health Organization, Geneva, Switzerland. 267–307.
*Ikeda T, Kojima T, Yoshida M, . 1990. Pretreatment of rats with an organophosphorus insecticide, chlorfenvinphos, protects against subsequent challenge with the same compound. Fundam Appl Toxicol 14(3):560–567.2340983
*Imato T, Ishibashi N. 1995. Potentiometric butyrylcholine sensor for organophosphate pesticides. Biosensors & Bioelectronics 10(5):435–441.7786469
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Cincinnati, OH.
*IRIS. 1996. Integrated Risk Information System. U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Cincinnati, OH.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals (IRPTC file). Data profile series no. 5. Geneva, Switzerland: United Nations Environmental Programme.
*Ivey MC, Clabom HV. 1969. GLC (gas-liquid-chromatographic) determination of dichlorvos in milk, eggs, and various body tissues of cattle and chickens. J Assoc Off Anal Chem 52(6): 1248–1251.
*Ivnitskii DM, Rishpon J. 1994. A potentiometric biosensor for pesticides based on the thiocholine hexacyanoferrate (iii) reaction. Biosensors & Bioelectronics 9(8):569–576.
*Jayasuriya VU, De S, Ratnayake WE. 1973. Screening of some pesticides on Drosophila melanogaster for toxic and genetic effects. Drosophila Inf Serv 50: 184–186.
*Johnson MK. 1978. The anomalous behavior of dimethyl phosphates in the biochemical test for delayed neurotoxicity. Arch Toxicol 41: 107–110.718419
*Johnson MK. 1981. Delayed neurotoxicity: Do trichlorfon and/or dichlorvos cause delayed neuropathy in man or test animals ? Acta Pharmacol Toxicol 49:87–98.
*Julka D, Pal R, Gill KD. 1992. Neurotoxicity of dichlorvos: effect on antioxidant defense system in the rat central nervous system. Exp Mol Path01 56(2):144–152.
*Kadenczki L, Arpad Z, Gardi I, . 1992. Column extraction of residues of several pesticides from fruits and vegetables: A simple multiresidue analysis method. J Assoc Off Anal Chem Int. 751:53–61.
*Kadokami K, Morimoto M, Haraguchi K, . 1991. Multiresidue determination of trace pesticides in water by gas chromatography/mass spectrometry with selected ion monitoring. Anal Sci 7(2):247–252.
*Kan-Do Office and Pesticide Team. 1995. Accumulated pesticide and industrial chemical findings from a ten year study of ready-to-eat foods. J AOAC Int 78(3):614–630.7756874
*Kawamoto K, Urano K. 1989. Parameters for predicting fate of organochlorine pesticide in the environment (1) Octanol-water and air-water partition coefficients. Chemosphere 18: 1986–1989.
*Kawasaki S, Ueda H, Itoh H, . 1992. Screening of organophosphorus pesticides using liquid chromatography-atmospheric pressure chemical ionization mass spectrometry. J Chromatogr 595(1-2):193–202.
*Kelly TJ, Mukund R, Spicer CW, . 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28(8):378A–387A
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotox Environ Safety 9(4):26–38.
*Kikuchi H, Suzuki Y, Hashimoto Y. 1981. Increase of beta glucuronidase activity in the serum of rats administered organophosphate and carbamate insecticides. J Toxicol Sci 6(1):27–36.7265327
*Kligerman AD, Exexson GL, Wilmer JL. 1985. Induction of sister chromatid exchange (SCE) and cell-cycle inhibition in mouse peripheral blood B lymphocytes exposed to mutagenic carcinogens in vivo. Mutat Res 157:181–187.3875033
*Kozlowska A, Sadurska B, Szymczyk T. 1988. Effect of dichlorvos on the activity of lipoprotein lipase from adipose tissue, on plasma lipids and posthepatin lipolytic plasma activity in rats. Arch Toxicol 62(2-3):227–229.3196159
*Kramers PGN, Knaap AGAC. 1978. Absence of a mutagenic effect after feeding dichlorvos to larvae of Drosophila melanogaster. Mutat Res 57(1): 103–105.417243
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Principles and methods of toxicology. 3rd edition, Wallace Hayes, ed. Raven Press, Ltd. New York, NY.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Toxicology of chemical mixtures, R.S.A. Yang, ed. Academic Press, New York, NY.
*Kusic R, Jovanovic D, Randjelovic S, . 1991. HI-6 in man: efficacy of the oxime in poisoning by organophosphorus insecticides. Hum Exp Toxicol 10(2): 113–118.1675101
*Lacorte S, Ehresmann N, Barcelo D. 1995. Stability of organophosphorus pesticides on disposable solid-phase extraction precolumns. Environ Sci Tech 29(11):2834–2841.
*Lamoreaux RF, Newland LW. 1978. The Fate of Dichlorvos in Soil. Chemoshpere 10:807–814.
*Lartiges S, Garrigues P. 1993. Determination of organophosphorus and organonitrogen pesticides in water and sediments by GC-NPD and GC-MS. Analusis 21(3):157–165.
*Lartiges SB, Garrigues PP. 1995. Degradation kinetics of organophosphorus and organonitrogen pesticides in different waters under various environmental conditions. Environ Sci Technol 29: 1246–1264.22192018
*Latif S, Haken JK, Wainwright S, . 1984. Gas chromatographic analysis of insecticidal preparations using carbon dioxide propellants. J Chromatogr 287:77–84.
*Leary JS, Kenae WT, Fontenot C, . 1974. Safety Evaluation in the Home of Polyvinyl Chloride Resin Strip Containing Dichlorvos (DDVP). Arch Environ Health 29:308–314.4429398
*Lehotay SJ, Eller KI. 1995. Development of a method of analysis for 46 pesticides in fruits and vegetables by supercritical fluid extraction and gas chromatography/ion trap mass spectrometry. J AOAC Int 78(3):821–830.7756898
*Leighton BL, Cheek TG, Gross JB, . 1986. Succinylcholine pharmacodynamics in peripartum patients. Anesthesiology 64(2):202–205.3946807
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. General and Applied Toxicology. Vol. I. Ballantine B, Marro T, Turner T, eds. Stockton Press New York, NY. 153–164.
*Lewis RG, Bond AE, Johnson DE, . 1988. Measurement of Atmospheric Concentrations of Common Household Pesticides: A Pilot Study. Environ Monit Assess 10:59–73.24248528
*Lieberman MT, Alexander M. 1983. Microbial and Nonenzymatic Steps in the Decomposition of Dichlorvos (2,2-Dichlorovinyl O,O-Dimethyl Phosphate). J Agric Food Chem 31(2):265–267.
*Liu J, Suzuki O, Kumazawa T, . 1989. Rapid isolation with Sep-Pak C18 cartridges and wide-bore capillary gas chromatography of organophosphate pesticides. Forensic Sci Int 41(1):67–72.2767581
*Lockridge O. 1990. Genetic variants of human serum cholinesterase influence metabolism of the muscle relaxant succinylcholine. Pharmacol Ther 47(1):35–60.2195556
*Loeffler JE, De Vries DM, Young R, . 1971. Metabolic fate of inhaled dichlorvos in pigs. Toxicol Appl Pharmacol 19:378.
*Loeffler JE, Potter JC, Scordelis SL, . 1976. Long term exposure of swine to a 14C dichlorvos atmosphere. J Agric Food Chem 24(2):367–371.1254816
*Lofroth G. 1970. Alkylation of DNA by dichlorvos. Radiobiology Department of the Biochemistry Institute University of Stockholm, Stockholm, Sweden.
*Lopez-Avila V, Dodhiwala NS, Beckert WF. 1990. Supercritical fluid extraction and its application to environmental analysis. J Chromatogr Sci 28(9):468–476.
*Lotti M, Johnson MK. 1978. Neurotoxicity of organophosphorus pesticide: Predictions can be based on in vitro studies with hen and human enzymes. Arch Toxicol 41:215–221.736792
*Mackison FW. 1981. Occupational health guidelines for chemical hazards. U.S. Department of Health and Human Services, Public Health Service, Washington, DC. DHHS (NIOSH) Publ. No. 81-123.
*Mali BD, Garad MV, Patil VB, . 1995. Thin-layer chromatographic detection of dichlorvos and dimethoate using orcinol. J Chromatogr A 704(2):540–543.
*Markell CG, Hagen DF, Luedtke JD. 1994. Solid phase extraction medium for wastewater treatment. U.S. Patent No. 5,279,742.
*Marking LL. 1992. Evaluation of Toxicants for the Control of Carp and other Nuisance Fishes. Fisheries 17:6–11.
*Martorell D, Cespedes F, Martinez FE, . 1994. Amperometric determination of pesticides using a biosensor based on a polishable graphite-epoxy biocomposite. Analytica Chimica Acta 290(3):343–348.
*Maslinska D, Lewandowska I, Prokopczyk J. 1981. Effect of prolonged acetylcholinesterase inhibition on postnatal brain development in rabbit. I. Level of serotonin in different brain regions. Acta Neuropathol Suppl (Berl) 7:52–55.6939284
*Maslinski S, Ciurzynska G, Maslinska D. 1979. Dichlorvos intoxication and gastric secretion. Acta Physiol Pol 30(5-6):657–660.119426
*Mathias CG. 1983. Persistent contact dermatitis from the insecticide dichlorvos. Contact Derm 9(3):217–218.
*Maxwell DM. 1992. The specificity of carboxylesterase protection against the toxicity of organophosphorus compounds. Toxicol Appl Pharmacol 114:306–312.1609424
*McHenery JG, Saward D, Seaton DD. 1991. Lethal and sub-lethal effects of the salmon delousing agent dichlorvos on the larvae of the lobster (Homarus gammarus L.) and herring (Clupea harengus L.). Aquaculture 98:331–347.
*Menz M Luetkemeier, H. Sachsse K. 1974. Long-term exposure of factory workers to dichlorvos (DDVP) insecticide. Arch environ health 28:72–76.4809916
*Menzie CM. 1972. Fate of Pesticides in the Environment. Ann Rev Entomol 17:199–222.4550533
*Merck. 1989. Merck index: an encyclopedia of chemicals, drugs, and biologicals. 1 lth ed. Budavari S, ed. Merck & Co., Inc., Rahway, NJ.
*Ministry of Agriculture, Fisheries and Food. 1977. Determination of residues of organophosphorus pesticides in fruits and vegetables. Analyst 102:858–868.596629
*Minyard JP Jr., Roberts WE. 1991. State Findings on Pesticide Residues in Foods 1988 and 1989. J Assoc Off Anal Chem 74(3):438–452.1874687
*Miyahara M, Okada Y, Takeda H, . 1994. Multiresidue procedures for the determination of pesticides in food using capillary gas chromatographic, flame photometric, and mass spectrometric techniques. Journal of Agricultural and food Chemistry 42(12):2795–2802.
*Mohammad FK, al-Kassim NA, Abdul-Latif AR. 1989. Effect of diphenhydramine on organophosphorus insecticide toxicity in mice. Toxicology 58(1):91–95.2815094
*Moriearty PL, Thornton SL, Becker RE. 1993. Transdermal patch delivery of acetylcholinesterase inhibitors. Meth Find Exp Clin Pharmacol 15(6):407–412.
*Moriya M, Kato K, Shirausu Y. 1978. Effects of cysteine and a liver metabolic activation system on the activities of mutagenic pesticides. Muta Res 57:259–263.
*Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116: 185–216.6339892
*Moutschen-Dahmen J, Moutschen-Dahmen M, Degraeve N. 1981. Metrifonate and dichlorvos: cytogenetic investigations. Acta Pharmacol Toxicol (Copenh) 49:29–39.7344409
*Mueller DK. 1992. Dichlorvos Under Siege. Pest Control 60(1):44–46.
*Nag M. 1992. Effect of organophosphate pesticides on glutaminase synthetase activity in rat brain. Indian J Exp Biol 30(6):543–545.1354653
*Nakamura Y, Sekiguchi S, Hasegawa S, . 1993. Reductions in Postharvest-Applied Dichlorvos, Chlorpyrifos-methyl, malathion, Fenitrothion, and Bromide in Rice during Storage and Cooking Processes. J Agric Food Chem 41(11):1910–1915.
*Nakamura Y, Tonogai Y, Sekiguchi Y, . 1994. Multiresidue analysis of 48 pesticides in agricultural products by capillary gas chromatography. Journal of Agricultural and Chemistry 42(11):2508–2518.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. National Academy Press, Washington, DC. 15–35.
*NCI. 1977. Bioassay of dichloryos for possible carcinogenicity (CAS No. 62-73-7). Carcinogenesis technical report series No. 10. National Cancer Institute, National Institutes of Health, Public Health Service, Department of Health, Education, and Welfare, Bethesda, MD. 1–98.
*Nichol AW, Angel LA. 1984. A comparative study of porphyrin accumulation in tissue cultures of chicken embryo hepatocytes treated with organophosphorus pesticides. Biochem Pharmacol 33(15):2511–2515.6466365
*Nicholas AH, Vienne M, Van Den Berghe H. 1978. Sister chromatid exchange frequencies in cultured human cells exposed to an organophosphorus insecticide dichlorvos. Toxicol Lett 2:271–275.
*Nicolau GY. 1983. Circadian rhythms of RNA, DNA and protein in the rat thyroid, adrenal and testis in chronic pesticide exposure. III. Effects of the insecticides (dichlorvos and trichlorphon). Physiologie 20(2):93–101.6196799
*NIOSH. 1990. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health, U.S. Dept. of Health and Human Services, Cincinnati, OH.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health, compendium of policy documents and statements. National Institute for Occupational Safety and Health, U.S. Dept. of Health and Human Services, Cincinnati, OH.
*NIOSWOSHA. 1981. Occupational Health Guidelines for Chemical Hazards. U. S. Department of Health and Human Services, Public Health Services, Centers for Disease Control, National Institute for Safety and Health Administration. Publication No. 81-123.
*Nishio A, Uyeki EM. 1982. Nuclease sensitivity of methylated DNA as a probe for chromatin reconstitution by genotoxicants. Biochemical Biophysical Research Communications 107(2):485–491.7126225
*NOES. 1991. National Occupational Exposure Survey (1981-1983): Dichlorvos. National Institute for Occupational Safety and Health, U.S. Department of Health and Human Services, Cincinnati, OH.
*Nordgren I. 1981. Quantitation of metrifonate and dichlorvos in blood and tissues by gas chromatography-mass spectrometry. Fundam Appl Toxicol 1(2):230–237.7184787
*Nordgren I, Bengtsson E, Holmsted B, . 1981. Levels of metrifonate and dichlorvos in plasma and erythrocytes during treatment of schistosomiasis with Bilarcil. Acta Pharmacol Toxicol Suppl. 49(5):79–86.
*NTP. 1989. Toxicology and carcinogenesis studies of dichlorvos in F344/N rats and B6C3F1 mice (gavage studies). NTP Technical Report TR 324, NIH Publication No. 89-2398. National Toxicology Program, National Institutes of Health, U. S. Department of Health and Human Services. Research Triangle Park, NC.
*NTP. 1995. Printed long term technical reports and short term toxicity study reports. National Toxicology Program. Management Status Report. Division of Toxicology Research and Testing. National Institute of Environmental Health Sciences. July 7, 1995.
*Okumura D, Melnicoe R, Jackson T, . 1991. Pesticide Residues in Food Crops Analyzed by the California Department of Food and Agriculture in 1989. Rev Environ Contam Toxicol 118:87–151.1992493
*OSHA. 1974. U.S. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1986. Chlorpyrifos, DDVP, diazinon, malathion, parathion. Method 62. Organic Methods Evaluation Branch, OSHA Analytical Laboratory, Occupational Safety and Health Administration, Salt Lake City, UT.
*OSU. 1992. Ohio Livestock Manure and Wastewater Management Guide. Bulletin 604. Ohio Cooperative Extension Service, Ohio State University, Columbus, OH.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Pachecka J, Grzadkowska K, Gajewski K. 1980. The activity of plasma phosphatases in rats treated with single doses of dichlorvos and trichlorphon. Acta Physiol Pol 31(5):555–559.7234436
*Pachecka J, Sulinski A, Traczykiewicz K. 1977. The effect of acute intoxication by dichlorvos and trichlorphon on the activities of some rat brain esterases. Neuropatol Pol 15(1):85–92.840392
*Paik SG, Lee SY. 1977. Genetic effects of pesticides in the mammalian cells. I. Induction of micronucleus. Korean J Zoo 120: 19–28.
*PIP-Dichlorvos. 1993. EXOTOXNET Profile for Dichlorvos. Extension Toxicology Network, Pesticide Information Project, Cornell University, Ithaca, NY.
*PIP-Naled. 1994. EXOTOXNET Profile for naled. Extension Toxicology Network, Pesticide Information Project, Cornell University, Ithaca, NY.
*PIP-Trichlorfon. 1993. EXOTOXNET Profile for Trichlorfon. Extension Toxicology Network, Pesticide Information Project, Cornell University, Ithaca, NY.
*Potter JC, Boyer AC, Marxmiller RL, . 1973a. Radioisotope residues and residues of dichlorvos and its metabolites in pregnant sows and their progeny dosed with dichlorvos-14C or dichlorvos- 36C1 formulated as PVC pellets. J Agric Food Chem 21(4):734–738.4718944
*Potter JC, Loeffler JE, Collins RD, . 1973b. Carbon-14 balance and residues of dichlorvos and its metabolites in pigs dosed with dichlorvos-14C. J Agric Food Chem 21(2):163–166.4688899
*Rasmussen WA, Jensen JA, Stein WJ, . 1963. Toxicological Studies of DDVP for Disinsection of Aircraft. Aerospace Med 34593-600.
*Reiner E, Plestina R. 1979. Regeneration of cholinesterase activities in humans and rats after inhibition by O,O-dimethyl-2,2-dichlorovinyl phosphate. J Toxicol Appl Pharmacol 49(3):451–454.
*Reiner E, Simeon V, Skrinjaric-Spoljar M. 1980. Hydrolysis of O,O-dimethyl-2,2-dichlorovinyl phosphate (DDVP) by esterases in parasitic helminths, and in vertebrate plasma and erythrocytes. Comp Biochem Physiol 66(2):149–152.
*Roinestad KS, Louis JB, Rosen JD. 1993. Determination of pesticides in indoor air and dust. J Assoc Off Anal Chem Int 76(5):1121–1126.
*Roes AH, Van Munsteren AJ, Nab FM, . 1987. Universal extraction/cleanup procedure for screening of pesticides by extraction with ethyl acetate and size exclusion chromatography. Anal Chim Acta 196:95–102.
*Schmidt G, Schmidt M, Nenner M, . 1979. Effects of dichlorvos (DDVP) inhalation on the activity of acetylcholinesterase in the bronchial tissue of rats. Arch Toxicol 42(3): 191–198.475593
*Schultz DR, Marxmiller RL, Koos BA. 1971. Residue determination of dichlorvos and related metabolites in animal tissue and fluids. J Agric Food Chem 19(6):1238–1243.5132656
*Schwetz BA, Ioset HD, Leong BK, . 1979. Teratogenic potential of dichlorvos given by inhalation and gavage to mice and rabbits. Teratology 20 (3):383–387.542893
*Segerback D, Ehrenberg L. 1981. Alkylating properties of dichlorvos (DDVP). Acta Pharmacol Toxicol 49:56–66.
*Shellenberger TE, Newell GW, Okamoto SS, . 1965. Response of rabbit whole blood cholinesterase in vivo after continuous intravenous infusion and percutaneous application of dimethyl organophosphate inhibitors. Biochem Pharm 14:943–952.5835874
*Shevchuk IA, Dubchenko YG, Grudneva GE. 1987. Solvent extraction isolation and separate determination of glyphosate and dichlorvos in aqueous solutions. J Anal Chem USSR 42(2):267–270.
*Shirasu Y, Moriya M, Kato K, . 1976. Mutagenicity screening of pesticides in the microbial system. Mutat Res 40(1): 19–30.814455
*Siers DG, Schooley MA, Brown LJ, . 1977. Management program for improving sow and gilt performance by feeding dichlorvos. Am J Vet Res 38(12): 1997–1999.596698
*Sittig M. 1980. Pesticide Manufacturing and Toxic Materials Control Encyclopedia. Noyes Data Corporation, Park Ridge, NJ. 293–294.
*Sittig M. 1985. Handbook of Toxic and Hazardous Chemicals and Carcinogen, Second Edition. Noyes Data Corporation, Park Ridge, NJ. 334–335.
*Sittig M. 1994. World-wide limits for toxic and hazardous chemicals in air, water and soil. Noyes Data Corporation, Park Ridge, NJ.
*Smart NA. 1977. Determination of residues of organophosphorus pesticides in fruits and vegetables. Analyst (LONDON) 202(1):858–868.
*Snow DH, Watson AD. 1973. The acute toxicity of dichlorvos in the dog. 1. Clinical observations and clinical pathology. Aust Vet J 49(3):113–119.4707161
*Snyder JL, Grob RL, Mcnally ME, . 1992. Comparison of supercritical fluid extraction with classical sonication and soxhlet extractions for selected pesticides. Anal Chem 64(17): 1940–1946.
*Sobels FH, Todd NK. 1979. Absence of a mutagenic effect of dichlorvos in Drosophila melanogaster. Mutat Res 67(1):89–92.111118
*SRC. 1994. Syracuse Research Center. Henry’s Law Program (HENRYWIN) version 2.50, serial H0142. Chemical hazard assessment division, Environmental Chemistry Center, Syracuse, NY.
*SRC. 1995. Syracuse Research Center. Atmospheric Oxidation Program(AOPWIN) version 1.65, serial 0156. Chemical Hazard Assessment Division, Environmental Chemistry Center, Syracuse, NY.
*SRI. 1994. Stanford research institute. 1994 Directory of chemical producers, United states of America. SRI international, Menlo park, CA. 103.
*Stanton HC, Albert JR, Mersmann HJ. 1979. Studies on the pharmacology and safety of dichlorvos in pigs and pregnant sows. Am J Vet Res 40(3):315–320.475081
*Sunshine. 1969. Handbook of Analytical Toxicology.
*Swarm RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters OctanoVwater partition coefficient, soil sorption constant, water to air ratio, and water solubility. Bow Chemical Company, Springer-Veriag New York Inc.
*Takahashi H, Kato A, Yamashita E, . 1987. Potentiations of N-methylcarbamate toxicities by organophosphorus insecticides in male mice. Fundam Appl Toxicol 8(2):139–146.2951289
*Takamiya K. 1994. Monitoring of urinary alkyl phosphates in pest control operators exposed to various organophosphorus Insecticides. Bull Environ Contam Toxicol 52(2): 190–195.8123977
*Taylor P, Li Y, Camp S, . 1993. Structure and regulation of expression of the acetylcholinesterase gene. Chem Biol Interactions 87: 199–207
*Teichert K, Szymczyk T, Consolo S, . 1976. Effect of acute and chronic treatment with dichlorvos on rat brain cholinergic parameters. J Toxicol Appl Pharmacol 35(1):77–81.
*Tewari SN, Harpalani SP. 1977. Determination of DDVP insecticide (dichlorvos) in biological fluids using TLC and calorimetry. J Indian Acad Forensic Sci 16(2):14–19.
*Tewari SN, Harpalani SP, Shatma VK. 1974. Toxicological analysis of autopsy tissues in cases of suicide by Flit insecticide. Proc Nat1 Acad Sci India, Sect. A 44 (Pt. 3):206–210.
*Tezuka H, Ando N, Suzuki R, . 1980. Sister chromatid exchanges and chromosomal aberrations in cultured Chinese hamster cells treated with pesticide positive in microbial reversion assays. Muta Res 78(2):177–191.
*The Agrochemicals Handbook. 1991. Dichlorvos. Royal Society of Chemistry Information services. Thomas Graham House Science Park, Milton Rd.
*Thier HP, Zeumer H. 1987. Manual of pesticide residue analysis, VOL. 1. H.P. Thier and H. Zeumer, eds. VCH Publishers INC., New York, NY.
*Thorpe E, Wilson AB, Dix KM, . 1972. Teratological studies with dichlorvos vapor in rabbits and rats. Arch Toxicol 30(1):29–38.
*Toxlist. 1995. EPA proposes to cancel most uses of pesticide dichlorvos and restrict retained uses. Fax Correspondence.
*Traverse R, Moretto A, Lotti M. 1989. Human serum “A”-esterases. Hydrolysis of O,O-dimethyl-2,2-dichlorovinyl phosphate. Biochem Pharmacol 38(4):671–676.2537085
*TRI92. 1994. Toxic chemical release inventory. Office of toxic Substances, U.S. Environmental Protection Agency, Washington, DC.
*TRI93. 1995. Toxics Release Inventory 1992. Office of Toxic Substances, U.S. Environmental Protection Agency, Washington, DC.
*Tully O, Monissey D. 1989. Concentrations of Dichlorvos in Be&each Bui Bay, Ireland. Mar Pollut Bull 20(4): 190–191.
*Ueda A, Aoyama K, Manda F, . 1994. Delayed-type allergenicity of triforine (saprol (R) ) Contact Dermatitis 31 (3): 140–145.
*UN. 1985. Treatment and Disposal Methods for Waste Chemicals. Data Profile Series No. 5. International Register of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva, Switzerland.
*Unni LK, Hannant ME, Becker RE. 1992. High-performance liquid-chromatographic method using ultra-violet detection for measuring metriphonate and dichlorvos levels in human plasma. J Chromatogr Biomed Appl (111):99–103.
*Volpe LS, Biagioni TM, Marquis JK. 1985. In vitro modulation of bovine caudate muscarinic receptor number by organophosphates and carbamates. J Toxicol Appl Pharmacol 78(2):226–234.
*Wagstaff DJ, Winston FB. 1980. Infrared photographic measurement of pupillary effects of dichlorvos in Beagles. Am J Vet Res 41(6):958–959.7436090
*Wang WK, Huang SD. 1994. Determination of organophosphorus pesticides in water using C18 or Florisil Sep-Pak cartridge and gas chromatography with flame-photometric detection. J Chin Chem Sot (Taipei) 41(1):109–113.
*Whitmore RW, Immerman FW, Camann DE, . 1994. Non-Occupational exposures to pesticides for residents of two U. S. cites. Arch Environ Contam Toxicol 26:45–59.
*WHO. 1985. Specifications for pesticides used in public health insecticides, molluscicides, repellents, methods. 6th Edition. World Health Organization, Geneva, Switzerland.
*WHO. 1989. Dichlorvos. Environmental Health Criteria #79. World Health Organization, Geneva, Switzerland.
*WHO. 1992. Trichlorfon. Environmental Health Criteria #132. World Health Organization, Geneva, Switzerland.
*Witter RF, Gaines TB, Short JG, . 1961. Studies on the safety of DDVP for the disinsection of commercial aircraft. Bull World Health Org 24:635–642.13786106
*Wooder MF, Wright AS, King LJ. 1977. In vivo alkylation studies with dichlorvos at practical use concentrations. Chem Biol Interact 19(1):25–46.922973
*Worthing CR. 1983. The pesticide manual: A world compendium. 7th ed. British Crop Protection Council.
*Wright AS, Hutson DH, Wooder MF. 1979. The chemical and biochemical reactivity of dichlorvos. Arch Toxicol 42(1):1–18.378182
*Wright CG, Leidy RB. 1980. Insecticide Residues in the Air of Buildings and Pest Control Buildings. Bull Environ Contam Toxicol 24:582–589.6155163
*Wyrobek AJ, Bruce WR. 1975. Chemical induction of sperm abnormalities in mice. Proc Natl Acad Sci USA 72(11):4425–4429.1060122
*Yamano T, Morita S. 1992. Hepatotoxicity of trichlorfon and dichlorvos in isolated rat hepatocytes. Toxicology 76(1):69–77.1475794
*Yamashita S, Miyajima T, Takino A, . 1991. Analysis for pesticides in natural water by capillary GC and GC/MS. Anal Sci 7(Su):1165–1166.
*Yess NJ, Houston MG, Gunderson EL. 1991a. Food and Drug Administration Pesticide Residue Monitoring of Foods: 1978-1982. J Assoc Off Anal Chem 74(2):265–272.2050608
*Yess NJ, Houston MG, Gunderson EL. 1991b. Food and Drug Administration Pesticide Residue Monitoring of Foods: 1983-1986. J Off Anal Chem 74(2):273–280.
*Zegers BN, Hogenboom AC, Dekkers SEG, . 1994. Packed capillary supercritical fluid chromatography of organophosphorus pesticides: Selective detection and applications. J Microcolumn. 55–62.