# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of dichlorvos is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of dichlorvos is located in Table 3-2.

Table 3-1 Chemical Identity of Dichlorvos

Characteristic | Information | Reference
Chemical name | O,O-dimethyl-O-(2,2-dichlorovinyl)phosphate | Merck 1989
Synonym(s) | Phosphoric acid 2,2-dichloroethenyl dimethyl ester; phosphoric acid 2,2-dichlorovinyl dimethyl ester; 2,2-dichlorovinyldimethyl phosphate; dichlorophos; dichlorovos; DDVP; dichlorvos | Merck 1989; Worthing 1983
Registered trade name(s) | SD 1750; Astrobot; Atgard; Canogard; Dedevap; Dichlorman; Divipan; Equigard; Equigel; Estrosol; Herkol; Nogos; Nuvan; Task; Vapona; Verdisol | Merck 1989
Chemical formula | C_4_H_7_CI_2_O_4_P | Merck 1989
Chemical structure | [image] | Worthing 1983
Identification numbers:
CAS Registry | 62-73-7 | Merck 1989
NIOSH RTECS | TC 0350000 | HSDB 1996
EPA Hazardous Waste | No data
OHM/TADS | 7800015 | HSDB 1996
DOT/UN/NA/IMCO | NA 2783 Dichlorvos; UN 3018 Organophosphorus pesticides, liquid, toxic IMO 6.1 | HSDB 1996
HSDB | 319 | HSDB 1996
NCI | C00113 | HSDB 1996

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Dichlorvos

Property | Information | Reference
Molecular weight | 220.98 | Merck 1989
Color | Colorless to amber | Worthing 1983
Physical state | Liquid | Merck 1989
Melting point | No data
Boiling point at 0.05 mm Hg | 35 °C | Worthing 1983
at 20 mm Hg | 140 °C | Merck 1989
at 14 mm Hg | 120 °C | Sunshine 1969
at 760 mm Hg | 221 °C | Aster 1996 (calculated)
Density at 25 °C | 1.415 g/mL | Merck 1989
Odor | mild chemical odor | Mackison 1981
Odor | aromatic odor | Worthing 1983
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 10 mg/mL | Worthing 1983; Merck 1989
Water at 25 °C | 16 mg/mL | Kawamoto and Urano 1989
Organic solvent(s) | Miscible with alcohol and most organic solvents | Merck 1989;
Organic solvent(s) | Miscible with aromatic chlorinated hydrocarbons | Sunshine 1969
Partition coefficients:
Log K_ow_ | 1.16 | Kawamoto and Urano 1989
Log K_ow_ | 1.47 | Bowman and Sans 1983
Log K_oc_ | 1.45 | Kenaga 1980
Vapor pressure at 20 °C | 1.2×10^−2^ mm Hg | Sunshine 1969; Merck 1989
Henry’s law constant
25 °C | 6.61 × 10^−7^ atm-m^3^/mol | Domine et al. 1992
25 °C | 7.01 × 10^−8^ atm-m^3^/mol | ASTER (1996) (calculated)
25 °C | 8.58 × 10^−7^ atm-m^3^/mol | SRC 1994
Autoignition temperature | No data
Flashpoint | >79 °C | HSDB 1996
Flammability limits
at 25 °C | Nonflammable | Merck 1989
Atmospheric reaction rate constatns
Hydroxyl radicals | 9.408 × 10^−12^ cm^3^/molecule-sec | SRC 1995
Half-life with 5×10^5^ | 2 days | Howard 1991
hydroxyl radicals per cm^3^ Ozone reaction | 0.003579 × 10^−17^ cm^3^/molecule-sec | SRC 1995
Half-life with 7.0×10^11^ | 320 days | Howard 1991
ozone molecules per cm^3^ (first order)
Hydrolysis half-lives
pH = 5.4 | 3.2 days | Latif et al. 1984
pH = 6 | 0.32 days | Latif et al. 1984
pH = 7 | 0.2 days | Latif et al. 1984
T = 10 °C | 240 days | Faust and Suffet 1966
T = 20 °C | 61.5 days | Faust and Suffet 1966
T = 30 °C | 1.7 days | Faust and Suffet 1966
Other | Readily decomposes in strong acid or alkali; hydrolyzes in water | Sunshine 1969
Other | Decomposition products may include hydrogen chloride gas, phosphoric acid mist, and carbon monoxide | NIOSH, OSHA 1981
Other | Corrosive to iron and mild steel | Worthing 1983
Conversion factors (25 °C) | ppm (v/v) = 9.02 mg/m^3^ | Calculated
Conversion factors (25 °C) | mg/m^3^ = 0.11 ppm (v/v) | Calculated
Explosive limits | No data

HSDB = Hazardous Substance Data Bank; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; v/v = volume per volume