# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorizarion Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect-level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15 364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E29, Atlanta, Georgia 30333.

## Dichlorvos Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1996
Profile status: | Post-Public Comment, Final
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 2
Species: | rat

[underlined: MRL:][underlined: 0.002] [ ] mg/kg/day [x] ppm [ ] mg/m^3^

[underlined: Reference:] Schmidt G, Schmidt M, Nenner M, and Vetterlein F 1979 Effects of dichlorvos (DDVP) inhalation on the activity of acetylcholinesterase in the bronchial tissue of rats Arch. Toxicol 42: 191198 .

[underlined: Experimental design: (human study details or strain. number of animals per exposure/control group, sex, dose administration details):] Schmidt et al. (1979) reported on a study where male Sprague-Dawley rats were exposed to atmospheres containing dichlorvos for 3, 7, or 14 days to determine its effect on acetylcholinesterase activity in the bronchi and the blood. Groups of 3 rats were kept in 0.55 m^3^ gas cages and the dichlorvos atmosphere generated by suspended polyvinyl chloride strips impregnated with dichlorvos. These strips were hung in the cages 24 hours before the beginning of the experiment and the dichlorvos concentration determined by withdrawing a 10-liter sample of air and passing it through 2 wash bottles containing water. This water was then tested for its ability to inhibit a standard preparation of bovine erythrocyte membrane acetylcholinesterase. Comparison with known concentrations of dichlorvos in this assay allowed an estimate of dichlorvos concentration in the cage air to be made. Different sizes of dichlorvos strips were used to generate dichlorvos concentrations ranging from 0 to 56.64 mg dichlorvos/m. At the end of the exposure, blood samples were taken and the pulmonary and bronchial arteries were perfused to remove blood. The bronchial tree was scarified under a dissecting microscope, rinsed, and homogenized. Acetylcholinesterase activity was measured by automatic pH titration after the addition of acetylcholine iodide. Acetylcholinesterase activity was also detected histochemically by the thiolacetic acid method using neostigmine as a specific blocker. A NOAEL of 1.82 mg dichlorvos/m^3^ (0.2Q ppm) was identified for inhibition of erythrocyte acetylcholinesterase. This enzyme is always inhibited in cases of dichlorvos neurotoxicity.

[underlined: Effects noted in study and corresponding doses:]

Effect of Dichlorvos on Acetylcholinesterase Activity

[underlined: Dose] | [underlined: Bronchial AChE] (% inhibition) | [underlined: Erythrocyte AChE] (% inhibition)
0 mg dichlorvos/m^3^ | 0 | 0
0.83 mg/m^3^ (0.09 ppm) | 40 | 0
1.82 mg/m^3^ (0.20 ppm) | 46 | 0
4.32 mg/m^3^ (0.48 ppm) | 60 | 60
8.20 mg/m^3^ (0.91 ppm) | 90 | 80
16.32 mg/m^3^ (1.80 ppm) | 90 | 80
56.64 mg/m^3^ (6.3 ppm) | 85 | 100

[underlined: Dose end point used for MRL derivation:] 1.82 mg/m^3^ (0.20 ppm) for inhibition of erythrocyte acetylcholinesterase.

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [x] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NOAEL_[HEC]_ = NOAEL_[ANIMALI]_ × (human blood-gas partition coefficient/animal blood-gas partition coefficient). Since the blood-gas partitioning coefficients of dichlorvos are unknown for humans or rats, a default value of 1 is being used for this ratio. Thus, NOAEL_[HEC]_ = NOAE_[ANIMAL]_ = 0.2 ppm dichlorvos. Data were reported as pg dichlorvos per liter air; this value was converted to the recommended units for gases (ppm) by multiplying gg/L by 24.45 liters/mole (the standard value for the volume of a mole of contaminant at 760 mm Hg and 25 °C) and then dividing by the molecular weight of dichlorvos in grams per mole (220.98). The result is expressed as pg/g, which is equivalent to ppm.

[underlined: Was a conversion used from intermittent to continuous exposure?]

If so, explain: No, exposure was continuous.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

This is the only acute inhalation study available for derivation of an MRL. Bronchial homogenate acetylcholinesterase showed significant inhibition at 0.09 ppm. The authors stated that lengthening the exposure period to 7 or 14 days produced similar results, but did not provide any data.

The Permissible Exposure Level (PEL) for dichlorvos established by OSHA is O. 1 ppm for a 10-hour workday. Practical insecticidal use concentrations for dichlorvos are 0.025 ppm.

[underlined: Agency Contact (Chemical Manager):] | Patricia Richter
[underlined: Agency Review Date:] | 1st review:__________
[underlined: Agency Review Date:] | 2nd review:__________

## Dichlorvos Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1996
Profile status: | Post-Public Comment, Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Key to figure: | 7
Species: | rat

[underlined: MRL:] 0.0003 [ ] mg/kg/day [x] ppm [ ] mg/m^3^

[underlined: Reference:] Thorpe E, Wilson AB, Dix KM, and Blair D. (1972) Teratological studies with dichlorvos vapor in rabbits and rats. Arch. Toxikol. 30 29–38 4646172 .

[underlined: Experimental design: (human study details or strain, number of animals per exposure/control group. sex, dose administration details):] Groups of 15 pregnant Carworth E rats were exposed to atmospheres containing 0, 0.25, 1.25, or 6.25 mg/m^3^ (0, 0.03, 0.14, or 0.69 ppm) throughout their 20-day gestation period. At the end of 20 days, the rats were sacrificed and the uteri removed for examination. The number of live fetuses, late fetal deaths, and resorption sites were noted, and live fetuses were weighed and examined for external malformations. Exposure of dams to all three concentrations of dichlorvos had no effect on the number of fetal resorptions, late fetal deaths, litter size, or mean weight per fetus. Some of the dams exposed to atmospheres containing 0.69 ppm dichlorvos were less active than controls. Exposure at 0.03 ppm had no effect on erythrocyte or brain acetylcholinesterase. Exposure at 0.14 ppm resulted in a 29% inhibition of erythrocyte and a 28% inhibition of brain acetylcholinesterase, while exposure at 6.25 mg/m resulted in 88% inhibition of erythrocyte acetylcholinesterase and an 83% inhibition of brain acetylcholinesterase. Brain and erythrocyte acetylcholinesterase activities were inhibited 83% and 88% in dams in the high exposure (0.69) group, suggesting that acetylcholinesterase inhibition is not associated with teratogenicity. Measurement of acetylcholinesterase activities in the pups was not performed. A NOAEL of 0.03 ppm was established for the neurological effect of brain acetylcholinesterase inhibition.

[underlined: Effects noted in study and corresponding doses:]

Effect of Dichlorvos on Acetylcholinesterase Activity

Dose | Brain AChE (% inhibition) | Erythrocyte AChE (% inhibition)
0 ppm | 0% | 0%
0.03 ppm | 0% | 0%
0.14 ppm | 28% | 29%
0.69 ppm | 83% | 88%

[underlined: Dose end point used for MRL derivation:] 0.03 ppm for neurological effects of acetylcholinesterase inhibition.

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [x] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NOAEL_[HEC]_ = NOAEL_[ANIMAL]_ × (human blood-gas partition coefficient/animal blood-gas partition coefficient). Since the blood-gas partitioning coefficients of dichlorvos are unknown for humans or rats, a default value of 1 is being used for this ratio. Thus, NOAEL_[HEC]_ = NOAEL_[ANIMAL]_ = 0.03 ppm. Data were reported in the study as pg dichlorvos per liter air; this value was converted to the recommended units for gases (ppm) by multiplying gg/L by 24.45 liters/mole (the standard value for the volume of a mole of contaminant at 760 mm Hg and 25 °C) and then dividing by the molecular weight of dichlorvos in grams per mole (220.98). The result is expressed as μg/g, which is equivalent to ppm.

[underlined: Was a conversion used from intermittent to continuous exposure?]

If so, explain: Rats were exposed for 23 hours a day; 0.03 ppm × 23/24 = 0.0288 ppm = 0.03 ppm.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

A NOAEL for developmental effects of 0.69 ppm dichlorvos was established in this study; however, the neurological NOAEL of 0.03 ppm was chosen for derivation of the MRL because it is more relevant to the principal toxicity of dichlorvos.

The Permissible Exposure Level (PEL) for dichlorvos established by OSHA is 0.1 ppm for a 10-hour workday. Practical insecticidal use concentrations for dichlorvos are 0.025 ppm.

[underlined: Agency Contact (Chemical Manager):] | Patricia Richter
[underlined: Ageney Review Date:] | 1st review:__________
[underlined: Ageney Review Date:] | 2nd review:__________

## Dichlorvos Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1997
Profile status: | Post-Public Comment, Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Key to figure: | 16
Species: | rat

[underlined: MRL:] 0.00006 [ ] mg/kg/day [x] ppm [ ] mg/m^3^

[underlined: Reference:] Blair D, Dix KM, Hunt PF, Thorpe E, Stevenson DE, and Walker AIT 1976 Dichlorvos - A 2-year inhalation carcinogenesis study in rats. Arch. Toxicol 35:281–294 989297 .

[underlined: Experimental design: (human study details or strain, number of animals per exposure/control group, sex, dose administration details):] Groups of 50 Carworth E strain rats of both sexes were exposed to atmospheres containing 0, 0.05, 0.5, or 5.0 mg dichlorvos/m^3^ (0, 0.006, 0.06, or 0.6 ppm) for 2 years for 23 hours per day as part of a carcinogenicity study. At the end of the study, the surviving rats were killed, blood was collected and half the brain was used to determine brain acetylcholinesterase. Plasma cholinesterase and erythrocyte acetylcholinesterase were also measured. In males treated at 0.006 ppm a NOAEL for brain and erythrocyte acetylcholinesterase was identified. Females at this dose had a 12% reduction in erythrocyte acetylcholinesterase, this is also a NOAEL, since erythrocyte acetylcholinesterase inhibition of 20% or less is not considered an adverse effect.

[underlined: Effects noted in study and correspoding doses:]

Effect of Dichlorvos on Acetylcholinesterase Activity

Dose | Brain AChE (% inhibition) | Erythrocyte AchE (% inhibition)
0 ppm | 0 | 0
0.006 ppm | 0 (M) | 0 (M)
0.006 ppm | 0 (F) | 12 (F)
0.06 ppm | 10 (M) | 0 (M)
0.06 ppm | 10 (F) | 31 (F)
0.6 ppm | 79 (M) | 96 (M)
0.6 ppm | 81 (F) | 95 (F)

[underlined: Dose end point used for MRI, derivation:] 0.006 ppm for brain and erythrocyte acetylcholinesterase inhibition in male rats.

[x] NOAEL [ ] LOAEL

[underlined: Uncertaintv factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [x] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NOAEL_[HEC]_ = NOAEL_[ANIMAL]_ × (human blood-gas partition coefficient/animal blood-gas partition coefficient). Since the blood-gas partitioning coefficients of dichlorvos are unknown for humans or rats, a default value of 1 is being used for this ratio. Thus, NOAEL_[HEC]_ = NOAEL_[ANIMAL]_ = 0.006 ppm. Data were reported as μg dichlorvos per liter air; this value was converted to the recommended units for gases (ppm) by multiplying gg/L by 24.45 liters/mole (the standard value for the volume of a mole of contaminant at 760 mm Hg and 25 °C) and then dividing by the molecular weight of dichlorvos in grams per mole (220.98). The result is expressed as μg/g, which is equivalent to ppm.

[underlined: Was a conversion used from intermittent to continuous exposure?]

If so, explain: Rats were exposed for 23 hours a day; 0.006 ppm × 23/24 = 0.0058 ppm = 0.006 ppm.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

This is the only chronic inhalation study available for the derivation of an MRL. The EPA used this study to derive an RfC of 0.0005 mg dichlorvos/m for lifetime exposure to dichlorvos.

[underlined: Agency Contact (Chemical Manager):] | Patricia Richter
[underlined: Agency Review Date:] | 1 st review:__________
[underlined: Agency Review Date:] | 2nd review:__________

## Dichlorvos Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1997
Profile status: | Post-Public Comment, Final
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [ intermediate [ ] Chronic
Key to figure: | 14
Species: | rat

[underlined: MRL:] 0.004 [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference:] Teichert K, Szymczyk T, Consolo S, and Ladinsky H. (1976) Effect of acute and chronic treatinent with dichlorvos on rat brain cholinergic parameters. Toxicol and Appl Pharmacol 35 77–81 1258061 .

[underlined: Experimental design: (human study details or strain, number of animals per exposure/control group, sex, dose administration details):] Male Sprague-Dawley rats were treated daily for 14 days with 4 mg/kg dichlorvos by gavage in corn oil. Dichlorvos purity was 99%. Control animals received corn oil only. Ten animals were used in the control group and 11 in the treatment group. At the end of the 14 day dosing period, the rats were decapitated, the brains removed, homogenized in 10 volumes of 0.3% Triton X-IOO, and centrifuged for 10 minutes. Aliquots of the supernatant were assayed for acetylcholinesterase activity by the hydrolysis of radioactive acetylcholine.

[underlined: Effects noted in study and corresponding doses:]

| Effect of Dichlorvos on Brain Acetylcholinesterase Activity (μmoles acetylcholine hydrolyzed/gram wet weight/hour)
0 mg/kg/day | 4 mg/kg/day (from Table 1 of reference)
559.3 +/− 5.2 | 314.91 +/− 1.97

Dichlorvos treatment at 4 mg/kg/day over a 14-day period resulted in a 44% inhibition of brain acetylcholinesterase activity, which is considered a less serious LOAEL for neurological effects.

[underlined: Dose end point used for MRL derivation:] 4 mg/kg/day for a 44% inhibition of brain AChE activity.

[ ] NOAEL [x] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [x] 10 (for use ofa LOAEL)

[ ] 1 [ ] 3 [x] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals. list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

If so, explain: No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

This is the only reliable study located for acute duration oral exposure to dichlorvos where doses ranging from 5 to 10% of the LD_50_ were administered on a daily basis and brain acetylcholinesterase (one of the targets for dichlorvos) was measured rather than erythrocyte acetylcholinesterase. Most of the acute duration oral studies for dichlorvos in rodent species were LD_50_ studies; representative LD_50_ values for the rat range from 56 to 97.5 mg/kg (Durham et al. 1957; Gajewski and Katkiewicz 1981; Ikeda et al. 1990). The 44% inhibition of brain acetylcholinesterase reported in this study is considered a less serious LOAEL; clinical signs were not reported in this study, but in another oral dosing study in Fischer 344 rats (NTP 1989) over an 11-day period, no clinical signs of organophosphate neurotoxicity were reported in animals receiving up to 16 mg/kg/day dichlorvos. The major limitation of the study used to derive the MRL is that because of its design, a dose-response relationship was not demonstrated.

The FAO/WHO Joint Meeting on Pesticide Residues has established an acceptable daily intake of dichlorvos for humans of 0.004 mg/kg/day (FAO/WHO 1967).

[underlined: Aaency Contact (Chemical Manager):] | Patricia Richter
[underlined: Aaency Review Date:] | 1st review:__________
[underlined: Aaency Review Date:] | 2nd review:__________

## Dichlorvos Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1996
Profile status: | Post-Public Comment, Final
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Key to figure: | 27
Species: | human

[underlined: MRL:] 0.003 [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference:] Boyer AC, Brown LJ, Slomka MB, and Hine CH (1977) Inhibition of human plasma cholinesterase by ingested dichlorvos: effect of formulation vehicle. Toxicol. Appl. Pharmacol. 41 389-394 898205 .

[underlined: Experimental design: (human study details or strain. number of animals per exposure/control group, sex. dose administration details):] Boyer et al. (1977) reported on a study designed to determine if different formulations would change the effect of dichlorvos on serum cholinesterase and erythrocyte acetylcholinesterase. Plasma cholinesterase and erythrocyte acetylcholinesterase were determined twice a week for 3 weeks in 30 male volunteers. Twenty-four men with the most stable activities were used in the study. Two treatment groups of 6 men each received 0.9 mg dichlorvos 3 times daily either in a premeal capsule filled with cottonseed oil or in a 3-ounce container of gelatin. Two other groups of 6 men each received placebo capsules or gelatin. The treated volunteers received 0.9 mg dichlorvos 3 times a day or 2.7 mg/day. The average weight of the volunteers was 81 kg, resulting in an average dose of 0.033 mg/kg/day. Dosing was started and carried out for a 21-day period during which plasma cholinesterase and erythrocyte acetylcholinesterase were measured twice a week by a pH titration method. Following the termination of dosing, plasma and erythrocyte activities were monitored twice weekly for seven weeks. Each individual’s observation of cholinesterase activities was converted to a percentage of his pretrial average determinations. No clinical signs of neurotoxicity were noted in any of the subjects (tremor, pupillary response to light and skin moisture were assessed). A NOAEL of 0.033 mg dichlorvos/kg/day was observed for inhibition of erythrocyte acetylcholinesterase.

[underlined: Effects noted in study and corresponding doses:]

Effect of Dichlorvos on Cholinesterase Activity

[underlined: Dose] | [underlined: Serum ChE] (% inhibition) | [underlined: Erythrocyte AChE] (% inhibition)
0.033 mg/kg/day | 38% (capsule) | 0% (capsule)
0.033 mg/kg/day | 28% (gelatin) | 0% (gelatin)

[underlined: Dose end point used for MRI 4 derivation:] 0.033 mg/kg/day for inhibition of AchE activity.

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRI derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list comzersion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

If so, explain: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

The reduction of serum cholinesterase observed in the study confirms that dichlorvos was absorbed by the volunteers under these conditions. No signs of clinical neurotoxicity were observed at any time in the volunteers. The dose given appeared to have been chosen expressly to not cause inhibition of erythrocyte acetylcholinesterase. This study was chosen for MRL derivation because it was the only one located that defined a NOAEL for humans for the end point of erythrocyte acetylcholinesterase inhibition.

The FAO/WHO Joint Meeting on Pesticide Residues has established an acceptable daily intake of dichlorvos for humans of 0.004 mg/kg/day (FAO/WHO 1967).

[underlined: Agency Contact (Chemical Manager):] | Patricia Richter
[underlined: Agency Review Date:] | 1st review:__________
[underlined: Agency Review Date:] | 2nd review:__________

## Dichlorvos Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Dichlorvos
CAS number: | 62-73-7
Date: | September 1996
Profile status: | Post-Public Comment, Final
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Key to figure: | 38
Species: | dog

[underlined: MRL:] 0.0005 [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference:] AMVAC Chemical Corp. 1990 A 52-week chronic toxicity study on DDVP in dogs. Unpublished report dated August 6, 1990 submitted by AMVAC Chemical Corporation, Los Angeles CA. EPA-41593101 .

[underlined: Experimental design: (human study details or strain, number of animals per exposure/control group, sex. dose administration details):] In a chronic feeding study, groups of Beagle dogs (4 per sex per dose, approximately 6-7 months old) were administered dichlorvos daily by gelatin capsule for 52 weeks at dose levels of 0, 0.1, 1.0, and 3.0 mg/kg/day. Observations included clinical signs, body weight, food consumption, ophthalmology, blood chemistry, necropsy, and histopathology. The 0.1 mg/kg/day dose level was lowered to 0.05 mg/kg/day on day 22 due to inhibition of serum cholinesterase noted after 12 days on dichlorvos (the authors were attempting to assure a no-effect level for serum ChE). Serum cholinesterase and erythrocyte acetylcholinesterase were measured throughout the study (3 times prior to treatment, and during weeks 2, 6, 13, 26, 39, and 52). At termination of the study, the brain was weighed and brain acetylcholinesterase was measured. Histopathology was performed on the brain (with brainstem), cervical spinal cord, lumbar spinal cord and the sciatic nerve.

[underlined: Effects noted in study and corresponding doses:] The main clinical observations were soft feces and emesis. Soft feces did not appear to be related to dichlorvos administration. One male treated at 3.0 mg/kg/day experienced emesis on 29 different days in the study. One male experienced ataxia, salivation, and dyspnea on one day during week 33, these classical symptoms of organophosphate toxicity were thought to be from an accidental overdose although this was not confirmed. Serum cholinesterase was unchanged in the 0.05 mg/kg/day groups for both sexes. At 1.0 mg/kg/day, serum cholinesterase was decreased by 52.9% in males and 51.8% in females. Erythrocyte acetylcholinesterase was decreased by 53.4% in males and 45.2% in females. At 3.0 mg/kg/day, serum cholinesterase was decreased 71.5% in males and 64.6% in females. Erythrocyte acetylcholinesterase was decreased 85.1% in males and 81.1% in females. Levels of inhibition did not increase over time of measurement (2-52 weeks). At termination of the study, brain acetylcholinesterase was decreased 22% in males at 1.0 mg/kg/day, but not in females. At 3.0 mg/kg/day, brain acetylcholinesterase was decreased 47% in males and 29% in females. No treatment-related changes were seen on histopathology for the following tissues: brain with brainstem, cervical spinal cord, lumbar spinal cord, optic nerve, thoracic spinal cord, and sciatic nerve.

Effect of Dichlorvos on Acetylcholinesterase Activity

Dose (mg/kg/day) | Brain AChE (% inhibition) | Erythrocyte (% inhibition)
0 | 0 | 0
0.05 | 0 | 0
1.0 | 53.4 (M) | 22 (M)
1.0 | 45.2 (F) | 0(F)
3.0 | 85.1 (M) | 47 (M)
3.0 | 81.1(F) | 29(F)

[underlined: Dose end point used for MRT derivation:] NOAEL of 0.05 mg/kg/day for erythrocyte and brain acetylcholinesterase inhibition

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [x] 10 (for exfrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mglbody weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] The EPA used this as the principal study to establish an RD for dichlorvos of 0.0005 mg/kg/day.

[underlined: Agency Contact (Chemical Manager):] | Patricia Richter
[underlined: Agency Review Date:] | 1st review:__________
[underlined: Agency Review Date:] | 2nd review:__________