# 9 REFERENCES

* Not cited in text

ACGIH. 2005. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Albrecht W. 1987a. Occupational exposure to 1,3-dichloropropene (Telone II^®^) in Hawaiian pineapple culture. Arch Environ Health 42:286–291.3452296
Albrecht WN. 1987b. Toxicology and hazard assessment of 1,3-dichloropropene (II). Arch Environ Health 42:292–296.3330654
*Albrecht WN, Chenchin K. 1985. Dissipation of 1,2-dibromo-3-chloropropane (DBCP), cis-1,3-dichloropropene (1,3-DCP), and dichloropropenes from soil to atmosphere. Bull Environ Contam Toxicol 34:824–831.4016290
Albrecht WN, Hagadone MR, Chenchin K. 1986. Charcoal air sampling tube storage stability and desorption efficiencies of 1,3-dibromo-3-chloropropane and 1,3-dichloropropene. Bull Environ Contam Toxicol 36:629–634.3697538
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Atkinson R, Darnall KR, Lloyd AC, . 1979. Kinetics and mechanisms of the reactions of the hydroxyl radical with organic compounds in the gas phase. Adv Photochem 11:375–488.
Baker LW, Fitzell DL, Seiber JN, . 1996. Ambient air concentrations of pesticides in California. Environ Sci Technol 30:1365–1368.
Barnekow DE, Brown SM, Byrne SL, . 1995. Characterization of residues in soybeans grown in soil treated with 1,3-dichloropropene soil fumigant. Pestic Sci 43:211–219.
Barnekow DE, Byrne SL, Huskin MA, . 1996. Metabolic fate and distribution of [^14^C]1,3-dichloropropene in carrot, lettuce, radish, tomato and wheat. Abstr Pap Am Chem Soc 211(1-2):AGRO 38.
Bartels MJ, Brzak KA, Mendrala AL, . 2000. Mechanistic aspects of the metabolism of 1,3-dichloropropene in rats and mice. Chem Res Toxicol 13(11):1096–1102.11087431
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Batzer FR, Balcer JL, Peterson JR, . 1996. Fate of 1,3-dichloropropene in aerobic soils. ACS Symp Ser 652:60–78.
Bean RM, Thomas BL, Neitzel DA. 1985. Analysis of sediment matter for halogenated products from chlorination of power plant cooling water. In: Proceedings of the 5th Water Chlorination Conference. Canton, NY: Lewis Publishers Inc., 1357–1370.
Belser NO, Castro CE. 1971. Biodehalogenation: Metabolism of the nematocides cis- and trans-3-chloroallyl alcohol by a bacterium isolated from soil. J Agric Food Chem 19:23–26.5573233
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bi X, Sheng G, Feng Y, . 2005. Gas- and particulate-phase specific tracer and toxic organic compounds in environmental tobacco smoke. Chemosphere 61(10):1512–1522.15975627
Boesten JJ, Van der Pas LJ, Smelt JH, . 1991. Transformation rate of methyl isothiocyanate and 1,3-dichloropropene in water-saturated sand subsoils. Neth J Agric Sci 39:179–190.
Bond JA, Medinsky MA, Dutcher JS, . 1985. Disposition and metabolism of 2,3-[^14^C]dichloropropene in rats after inhalation. Toxicol Appl Pharmacol 78:47–54.4035672
Boogard PJ, Rocchi PS, van Sittert NJ. 1993. Effects of exposure to low concentrations of chlorinated hydrocarbons on the kidney and liver of industrial workers. Br J Ind Med 50:331–339.8494773
Bousema MT, Wiemer GR, van Joost T. 1991. A classic case of sensitization to DD-95. Contact Dermatitis 24(2):132–133.1828211
Breslin W, Kirk H, Streeter C, . 1989. 1,3-Dichloropropene: Two-generation inhalation reproduction study in Fischer 344 rats. Fundam Appl Toxicol 12:129–143.2925012
Brodzinsky R, Singh HB. 1982. Volatile organic chemicals in the atmosphere: An assessment of available data. Menlo Park, CA: Atmospheric Science Center SRI International, 155.
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington, DC: The C.V. Mosby Company, 53, 155–156.
Brouwer DH, Brouwer EJ, De Vreede JA, . 1991a. Inhalation exposure to 1,3-dichloropropene in the Dutch flower-bulb culture. Part I. Environmental monitoring. Arch Environ Contam Toxicol 20(1):1–5.
*Brouwer EJ, Evelo CT, Verplanke AJ, . 1991b. Biological effect monitoring of occupational exposure to 1,3-dichloropropene: Effects on liver and renal function and on glutathione conjunction. (Erratum to: Br J Ind Med 48(3):167-172). Br J Ind Med 48(4):288.2025599
Brouwer EJ, Verplanke AJ, Boogaard PJ, . 2000. Personal air sampling and biological monitoring of occupational exposure to the soil fumigant cis-1,3-dichloropropene. Occup Environ Med 57(11):738–744.11024197
Carreon R, Wall J. 1983. Telone II^®^: Skin sensitization potential in the guinea pig. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515850.
Castro CE, Belser NO. 1966. Hydrolysis of cis- and trans-1,3-dichloropropene in wet soil. J Agric Food Chem 14:69–70.
Castro CE, Belser NO. 1968. Biodehalogenation. Reductive dehalogenation of the biocides ethylene dibromide, 1,2-dibromo-3-chloropropane, and 2,3-dibromobutane in soil. Environ Sci Technol 2:779–783.26505514
CEPA. 1982. Monitoring of Telone II^®^ during and following experimental application by shank injection to established trees and grape vines in California in 1980 and 1981. Sacramento, CA: California Environmental Protection Agency, Department of Pesticide Regulation. Index of Worker, Health and Safety Reports, HS-967. http://www.cdpr.ca.gov/docs/whs/pdf/hs967.pdf. May 10, 2006.
Chem ID. 2006a. Cis 1,3-dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chem ID. 2006b. Trans 1,3-dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chem ID. 2006c. 1,1-Dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chem ID. 2006d. 1,2-Dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chem ID. 2006e. 2,3-Dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chem ID. 2006f. 3,3-Dichloropropene. Chem ID plus advanced. Betheseda, MD: National Library of Medicine.
Chung K-Y, Dickson DW, Ou L-T. 1999. Differential enhanced degradation of cis- and trans-1,3-D in soil with a history of repeated field applications of 1,3-D. J Environ Sci Health B 34(5):749–768.
Clary T, Ritz B. 2003. Pancreatic cancer mortality and organochlorine pesticide exposure in California, 1989-1996. Am J Ind Med 43(3):306–313.12594778
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Climie I, Hutson D, Morrison B, . 1979. Glutathione conjugation in the detoxication of (Z)-1,3-dichloropropene (a component of the nematocide DD^®^) in the rat. Xenobiotica 9:149–156.473791
Coate W. 1979a. Addendum to final report on the 90-day inhalation toxicity study in rats and mice - Telone II^®^. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515856.
Coate W. 1979b. Subacute inhalation toxicity study in rats and mice of Telone II^®^ (1,3-dichloropropene). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS50515834.
Cohen DB. 1986. Groundwater contamination by toxic substances. A California assessment. In: American Chemical Society Symposium Series. Washington, DC: American Chemical Society, 315, 499–529.
Connors TF, Stuart JD, Cope JB. 1990. Chromatographic and mutagenic analyses of 1,2-dichloropropane and 1,3-dichlropropylene and their degradation products. Bull Environ Contam Toxicol 44(2):288–293.2182142
Corazza M, Zinna G, Virgili A. 2003. Allergic contact dermatitis due to 1,3-dichloropropene soil fumigant. Contact Dermatitis 48(6):341–342.14531879
Cracknell S, Jackson G, Hardy C. 1987. Telone II^®^ (1,3-dichloropropene) - Acute inhalation study in rats - 4-hour exposure. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515821.
Crebelli R, Andreoli C, Carere A, . 1992. The induction of mitotic chromosome malsegregation in Aspergillus nidulans. Quantitative structure activity relationship (QSAR) analysis with chlorinated aliphatic hydrocarbons. Mutat Res 266(2):117–134.1373821
Creedy C, Brooks T, Dean B, . 1984. The protective action of glutathione on the microbial mutagenicity of the Z- and E-isomers of 1,3-dichloropropene. Chem Biol Interact 50:39–48.6375881
Cryer SA, van Wesenbeeck IJ. 2001. Predicted 1,3-dichloropropene air concentrations resulting from tree and vine applications in California. J Environ Qual 30:1887–1895.11789993
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and non-fatty foods. J Agric Food Chem 37:560–564.
Daft JL. 1990. Recovery of 1,3-, 2,3-dichloropropenes, 1,2-dibromo-3-chloropropane, and o-, p-dichlorobenzenes from fatty and non-fat foodstuffs by liquid extraction technique. Arch Environ Contam Toxicol 19(6):921–925.2256707
De Lorenzo F, Degl’innocenti S, Ruocco A, . 1977. Mutagenicity of pesticides containing 1,3-dichloropropene. Cancer Res 37:1915–1917.322862
De Zwart LL, Haenen HE, Versantvoort CH, . 2004. Role of biokinetics in risk assessment of drugs and chemicals in children. Regul Toxicol Pharmacol 39:282–309.15135209
Dietz F, Dittenber D, Kastl P. 1982. 1,3-Dichloropropene: Effects on tissue non-protein sulfhydryl content and blood concentration time profile-probe study. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515837.
Dietz FK, Grandjean M, Young JT. 1985b. 1-Hour LC50 determination in Fischer 344 rats - 2,3-dichloropropene. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515982.
Dietz FK, Hermann E, Kastl P, . 1985a. 1,3-Dichloropropene: Pharmacokinetics, effect on tissue non-protein sulfhydryls, and macromolecular binding in Fischer-344 rats and B6C3F1 mice following oral administration. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515836.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
DOT. 2000. 1,3-Dichloropropene. 2000 Emergency response guidebook (ERG2000). Washington, DC: U.S. Department of Transportation.
Dow. 1962. Results of range finding toxicological tests on 1,2-dichloropropene. Rockville, MD: Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510189.
Dowty BJ, Carlisle DR, Laseter JL. 1975a. New Orleans drinking water sources tested by gas chromatography-mass spectrometry. Occurrence and origin of aromatics and halogenated aliphatic hydrocarbons. Environ Sci Technol 9:762–765.
Dowty B, Carlisle D, Laseter J, . 1975b. Halogenated hydrocarbons in New Orleans drinking water and blood plasma. Science 187:75–77.1109227
Dutcher JS, Medinsky MA, Bond JA, . 1985. Effect of vapor concentration on the disposition of inhaled 2,3-dichloropropene in Fischer-344 rats. Fundam Appl Toxicol 5:997–1005.4065469
Eder E, Dornbusch K. 1988. Metabolism of 2,3-dichloro-1-propene in the rat. Consideration of bioactivation mechanisms. Drug Metab Dispos 16(1):60–68.2894957
Eder E, Dornbusch K, Fischer G. 1987. The role of biotransformation in the genotoxicity of allylic compounds. Arch Toxicol 60:182–186.3619639
Eder E, Henschler D, Neudecker T. 1982a. Mutagenic properties of allylic and α,β-unsaturated compounds: Consideration of alkylating mechanisms. Xenobiotica 12:831–848.6763406
Eder E, Neudecker T, Lutz D, . 1982b. Correlation of alkylating and mutagenic activities of allyl and allylic compounds: Standard alkylation test vs. kinetic investigation. Chem Biol Interact 38:303–315.7037213
Eder E, Schiffmann D, Dornbusch K, . 1986. Genotoxicity of allyl compounds – a quick screening strategy based on structure-activity relationships and a battery of prescreening tests. Food Chem Toxicol 24(6/7):667–673.3781422
Ellenhorn MJ, Schonwald S, Ordog G, . 1997. 1,3-Dichloropropene. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2nd ed. Baltimore, MD: Williams and Wilkins, 1656, 1657, 1659.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
El Hadiri N, Ammati M, Chgoura M, . 2003. Behavior of 1,3-dichloropropene and methyl isothiocyanate in undisturbed soil columns. Chemosphere 52:893–899.12757790
EPA. 1978a. Toxicity of secondary effluents from textile plants. In: Symposium proceedings: Process measurements for environmental assessment (Atlanta, February 1978). Washington, DC: U.S. Environmental Protection Agency, 153–169. EPA600778168.
EPA. 1978b. Analysis of organic air pollutants in the Kanawha Valley, WV and the Shenandoah Valley, VA. Philadelphia, PA: U.S. Environmental Protection Agency. EPA903978007.
EPA. 1979. Formulation of a preliminary assessment of halogenated organic compounds in man and environmental media. Washington, DC: U.S. Environmental Protection Agency, Toxic Substances. EPA5601379006. PB80112170.
EPA. 1980. Acquisition and chemical analysis of mother’s milk for selected toxic substances. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA5601380029.
EPA. 1981a. Treatability manual. Washington, DC: Office of Research and Development, U.S. Environmental Protection Agency, I.12.14-1 to I.12.14-5. EPA600880042a.
EPA. 1981b. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014.
EPA. 1981c. Vapor pressure distribution of selected organic chemicals (final report). Cincinnati, OH: U.S. Environmental Protection Agency. EPA600281021. PB81171233.
EPA. 1982. Test methods. Methods for organic chemical analysis of municipal and industrial wastewater: Test method purgeable halocarbons-method 601. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA6004282057.
EPA. 1986. Method 8010. Halogenated volatile organics. In: Test methods for evaluating solid wastes. Volume IB: Laboratory manual, physical/chemical methods: 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1987a. PCGEMS Graphical Exposure Modeling System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppt/cahp/actlocal/pcgems.html. June 12, 2006.
EPA. 1987b. Determination of Henry’s Law constants of selected priority pollutants. Cincinnati, OH: U.S. Environmental Protection Agency. PB87212684.
*EPA. 1987c. Appendix A: Reference dose (RfD): Description and use in health risk assessments. Integrated risk information system supportive documentation, Volume I. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600886032a.
EPA. 1988. National ambient volatile organic compounds (VOCs) data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA600388010a.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1991. 1990 Urban air toxics monitoring program. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450491024. PB92110022.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
EPA. 1995a. Method 524.2: Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 1995b. Method 502.2: Volatile organic compounds in water by purge and trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. Cincinnati, OH: National Exposure Research Laboratory, Office of Research and Development, U.S. Environmental Protection Agency. http://web1.er.usgs.gov/nemi/method_summary.jsp?param_method_id=4798. May 23, 2006.
EPA. 1996a. Method 8021B: Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. SW-846 online: Test methods for evaluating solid waste, physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8021b.pdf. April 05, 2006.
EPA. 1996b. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). SW-846 online: Test methods for evaluating solid waste, physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Reregistration Eligibility Decision (RED). Washington DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances. EPA738R98016.
EPA. 1999. USEPA contract laboratory program statement of work for organics analysis, multi-media, multi-concentration, OLM 4.2, exhibit A-D. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/superfund/programs/clp/olm4.htm#sow. May 15, 2006.
EPA. 2000a. Toxicological review of 1,3-dichloropropene. In support of summary information on the Integrated Risk Information System (IRIS). Washington DC: U.S. Environmental Protection Agency. EPA635R00001.
EPA. 2000b. Benchmark dose technical guidance document. Washington, DC: U.S. Environmental Protection Agency, Risk assessment Forum. EPA630R00001.
EPA. 2001a. Method 601: Purgeable halocarbons. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136 App. A, 31–44.
EPA. 2001b. Method 1624 revision B: Volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136 App. A, 274–287.
EPA. 2001c. Unregulated contaminant monitoring program. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/safewater/ucmr/ucm_rounds_1-2.html. March 25, 2006.
EPA. 2001d. Exploration of perinatal pharmacokinetic issues. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R01004. http://cfpub.epa.gov/ncea/raf/recordisplay.cfm?deid=29420. March 25, 2001.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2005b. Method 624: Purgeables. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136 App. A.
EPA. 2006a. Acute exposure guideline levels (AEGLs). Office of Pollution Prevention and Toxics. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/chemlist.htm. March 07, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr116.4.pdf. January 8, 2008.
EPA. 2006c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006d. Identification and listing of hazardous waste. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006f. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr302.4.pdf. January 08, 2008.
EPA. 2006g. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. httphttp://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf. January 08, 2008.
EPA. 2006h. Water quality standards. Toxics criteria for those states not complying with Clean Water Act section 303(c)(2)(B). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 131.36. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006i. 1,3-Dichloropropene. In: National pesticide information retrieval system. Washington, DC: U.S. Environmental Protection Agency. http://ppis.ceris.purdue.edu/htbin/rnamset.com. March 18, 2006.
EPA. 2006j. 1,3-Dichloropropene. Modernized STORET system: Regular results by geographic location (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. April 06, 2006.
EPA. 2006k. Protection of stratospheric ozone: The 2006 critical use exemption from the phaseout of methyl bromide. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 82.
*EPA. 2006l. 2,3-Dichloropropene. In: National pesticide information retrieval system. Washington, DC: U.S. Environmental Protection Agency. http://ppis.ceris.purdue.edu/htbin/rnamset.com. May 22, 2006.
FDA. 2005. Beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 8, 2008.
FEDRIP. 2006. 1,3-Dichloropropene. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fisher G, Kilgore W. 1988a. Tissue levels of glutathione following acute inhalation of 1,3-dichloropropene. J Toxicol Environ Health 23:171–182.3343694
Fisher G, Kilgore W. 1988b. Mercapturic acid excretion by rats following inhalation exposure to 1,3-dichloropropene. Fundam Appl Toxicol 11:300–307.3220208
Fisher G, Kilgore W. 1989. Pharmacokinetics of S-[3-chloroprop-2-enyl] glutathione in rats following acute inhalation exposure to 1,3-dichloropropene. Xenobiotica 19:269–278.2750198
Flessel P, Goldsmith J, Kahn E, . 1978. Acute and possible long-term effects of 1,3-dichloropropene-California. MMWR 27:5–55.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Franke C, Studinger G, Berger G, . 1994. The assessment of bioaccumulation. Chemosphere 29(7):1501–1514.
Gan J, Yates SR, Crowley D, . 1998a. Acceleration of 1,3-dichloropropene degradation by organic amendments and potential application for emissions reduction. J Environ Qual 27:408–414.
Gan J, Yates SR, Ernst FF. 1998b. Organic chemicals in the environment: Effect of application methods on 1,3-dichloropropene volatization from soil under controlled conditions. J Environ Qual 27:432–438.
Ghia M, Robbiano L, Allavena A, . 1993. Genotoxic activity of 1,3-dichloropropene in a battery of in vivo short-term tests. Toxicol Appl Pharmacol 120(1):120–125.8511773
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gollapudi BB, Cieszlak FS, Day SJ, . 1998. Dominant lethal test with rats exposed to 1,3-dichloropropene by inhalation. Environ Mol Mutagen 32(4):351–359.9882010
Granville CA, Ross MK, Tornero-Velez R, . 2005. Genotoxicity and metabolism of the source-water contaminant 1,1-dichloropropene: Activation by GSTT1-1 and structure-activity considerations. Mutat Res 572(1–2):98–112.15790493
Gunther FA, Westlake WE, Jaglan PS. 1968. Reported solubilities of 738 pesticide chemicals in water. Res Rev 20:1–148.
Guo M, Papiernik SK, Zheng W, . 2004. Effects of environmental factors on 1,3-dichloropropene hydrolysis in water and soil. J Environ Qual 33:612–618.15074813
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington DC: International Life Sciences Institute Press, 1–283.
Hamaker JW, Thompson JM. 1972. Adsorption. In: Goring CA, Hamaker JN, eds. Organic chemicals in the soil environment. Marcel Dekker Inc., 49–144.
Hanley T, John-Greene J, Young J, . 1987. Evaluation of the effects of inhalation exposure to 1,3-dichloropropene on fetal development in rats and rabbits. Fundam Appl Toxicol 8:562–570.3609542
Hartwig J, Sommer H, Muller F. 2005. Nematicides. In: Bohnet M, Brinker CJ, Cornils B, . eds. Ullmann’s encyclopedia of industrial chemistry. New York NY: John Wiley & Sons, Inc., 1–13.
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–272.24264296
Haut KT, Stebbins KE, Johnson KA, . 1996. Subchronic toxicity of ingested 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 32(2):224–232.8921325
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
HazDat. 2008. 1,3-Dichloropropene. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. June 11, 2008.
He F. 1993. Biological monitoring of occupational pesticides exposure. Int Arch Occup Environ Health 93:S69–S76.
Hernandez AF, Martin-Rubi JC, Ballesteros JL, . 1994. Clinical and pathological findings in fatal 1,3-dichloropropene intoxication. Hum Exp Toxicol 13(5):303–306.8043309
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
HSDB. 2006. 1,3-Dichloropropene. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. March 21, 2006.
Hutson D, Moss J, Pickering B. 1971. Excretion and retention of components of the soil fumigant DD^®^ and their metabolites in the rat. Food Cosmet Toxicol 9:677.5157560
IARC. 1986. IARC monographs of the evaluation of the carcinogenic risk of chemicals to humans. Vol. 41: 1,3-Dichloropropene. Lyon, France: International Agency for Research on Cancer, World Health Organization, 113–130.
IARC. 1999. 1,3-Dichloropropene. IARC Monogr Eval Carcinog Risk Chem Hum 71(3):933–945.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. March 08, 2006.
IRIS. 2006. 1,3 Dichloropropene. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. March 08, 2006.
IUR. 2002. Inventory update rule. Toxic Substance Control Act (TSCA) Inventory Update Database. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opptintr/iur/iur02/index.htm. March 08, 2006.
Jeffrey M. 1987a. Telone II^®^ soil fumigant: Dermal sensitization potential in the Hartley albino guinea pig. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515819.
Jeffrey M. 1987b. Telone II^®^ soil fumigant: Primary eye irritation study in New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517082.
Jeffrey M. 1987c. Telone II^®^ soil fumigant: Primary dermal irritation study in New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517081.
Jeffrey MM, Battjes JE, Lomax L. 1987a. Telone II^®^ soil fumigant: Acute oral toxicity study in Fischer 344 rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517080.
Jeffrey M, Schuetz D, Lomax L. 1987b. Telone II^®^ soil fumigant: Acute dermal toxicity study in New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515820.
Johannsen FR, Levinskas GJ, Rusch GM, . 1991. Subchronic inhalation toxicity and reproductive assessment in rats of three chlorinated propenes. J Toxicol Environ Health 33:291–302.1856878
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Jones J, Collier T. 1986a. Telone II^®^: OECD 401 acute oral toxicity test in the rat. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515823.
Jones J, Collier T. 1986b. Telone II^®^: OECD 401 acute dermal toxicity test in the rat. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515824.
Kastl PE, Hermann EA. 1983. Determination of cis- and trans-1,3-dichloropropene in whole rat blood by gas chromatography and gas chromatography - chemical ionization mass spectrometry with selected-ion monitoring. J Chromatogr 265:277–283.6630338
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
Kevekordes S, Gebel T, Pav K, . 1996. Genotoxicity of selected pesticides in the mouse bone-marrow micronucleus test and in the sister-chromatid exchange test with human lymphocytes in vitro. Toxicol Lett 89(1):35–42.8952709
Kezic S, Monster AC, Verplanke AJ, . 1996. Dermal absorption of cis-1,3-dichloropropene vapour: Human experimental exposure. Hum Exp Toxicol 15(5):396–399.8735463
Kim J-H, Gan J, Farmer WJ, . 2003a. Effect formulation on the behavior of 1,3-dichloropropene in soil. J Environ Qual 32:2223–2229.14674545
Kim J-H, Gan J, Farmer WJ, . 2003b. Organic matter effects on phase partition of 1,3-dichloropropene in soil. J Agric Food Chem 51:165–169.
Kitchin KT, Brown JL. 1994. Dose-response relationship for rat liver DNA damage caused by 49 rodent carcinogens. Toxicology 88:31–49.8160204
Kloes P, Calhoun L, Young J, . 1983. Telone II^®^: Inhalation teratology probe study in Fischer 344 rats and New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515853.
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992-1996. Ground Water 38(6):858–863.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.
Krahling L, Krey J, Jakobson G, . 2005. Allyl compounds. In: Bohnet M, Brinker CJ, Cornils B, . eds. Ullmann’s encyclopedia of industrial chemistry. New York NY: John Wiley & Sons, Inc., 1–15.
Krijgsheld KR, van der Gen A. 1986. Assessment of the impact of the emission of certain organochlorine compounds on the aquatic environment. Part II: Allylchloride, 1,3- and 2,3-dichloropropene. Chemosphere 15:861–880.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Lag M, Omichinski JG, Dybing E, . 1994. Mutagenic activity of halogenated propanes and propenes: Effect of bromine and chlorine positioning. Chem Biol Interact 93(1):73–84.
Lao RC, Thomas RS, Bastien P, . 1982. Analysis of organic priority and non-priority pollutants in environmental samples by GC/MS/computer systems. In: Albaiges J, ed. Analytical techniques in environmental chemistry II. New York, NY: Pergamon Press Ltd., 107–118.
Lee S, McLaughlin R, Harnly M, . 2002. Community exposures to airborne agricultural pesticides in California: Ranking of inhalation risks. Environ Health Perspect 110(12):1175–1184.12460795
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.
Leiber MA, Berk HC. 1984. Development and validation of an air-monitoring method for 1,3-dichloropropene, trans-1,2,3-trichloropropene, cis-1,2,3-trichloropropene, 1,1,2,3-tetrachloropropene, 2,3,3-trichloroprop-2-en-1-ol and 1,1,2,2,3-pentachloropropane. Anal Chem 56:2134–2137.6507858
Leistra M. 1970. Distribution of 1,3-dichloropropene over the phases in soil. J Agric Food Chem 18:1124
Lemen RA. 2001. Unsaturated halogenated hydrocarbons: 1,3-Dichloropropene. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. New York NY: John Wiley & Sons, Inc., 1–6. http://www.mrw.interscience.wiley.com/pattys/tox/articles/tox064/sect1.html. March 18, 2006.
Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
Lewis RJ. 2000. Dichloropropene. Sax’s dangerous properties of industrial materials. 10th ed. New York, NY: John Wiley & Sons, Inc., 1220–1222.
Lewis RJ, ed. 2001. 1,3-Dichloropropene. Hawley’s condensed chemical dictionary. 14th ed. New York, NY: John Wiley & Sons, Inc., 364.
Lichy C, Olson K. 1975. Acute toxicological properties of experimental nematicide formulation M-3993 containing 1,3-dichloropropene. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515857.
Lide DR. 2005. 1,3-Dichloropropene. CRC handbook of chemistry and physics. 86th ed. Boca Raton, FL: CRC Press, Inc., 3–160, 3–161.
Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.
Lomax L, Stott W, Johnson K, . 1989. The chronic toxicity and oncogenicity of inhaled technical grade 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 12:418–431.2731657
Loveday KS, Anderson BE, Resnick BE, . 1990. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: V. Results with 46 chemicals. Environ Mol Mutagen 16 (4):272–303.2253606
Loveday, KS, Lugo MH, Resnick MA, . 1989. Chromosome aberrations and sister chromatid exchange tests in Chinese hamster ovary cells in vitro. III. Results with 20 chemicals. Environ Mol Mutagen 13:60–94.2642806
Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt EH, eds. Handbook of chemical property estimation methods. Chapter 4. New York NY: McGraw Hill Book Co., 4–1 to 4–33.
Mackay D, Shiu WY. 1981. A critical review of Henry’s Law constants for chemicals of environmental interest. J Phys Chem Ref Data 10:1175–1199.
Maddy KT, Fong HR, Howe JA. 1982. A study of well water in selected California communities for residues of 1,3-dichloropropene, chloroallyl alcohol and 49 organophosphate or chlorinated hydrocarbon pesticides. Bull Environ Contam Toxicol 29:354–359.7126926
Markovitz A, Crosby WH. 1984. Chemical carcinogenesis. A soil fumigant, 1,3-dichloropropene, as possible cause of hematologic malignancies. Arch Intern Med 144:1409–1411.6587835
Martelli A. 1997. Primary human and rat hepatocytes in genotoxicity assessment. In Vivo 11(2):189–194.9179615
Matsuoka A, Hayashi M, Sofuni T. 1998. In vitro clastogenicity of 19 organic chemicals found in contaminated water and 7 structurally related chemicals. Kankyo Hen’igen Kenkho 20(3):159–165.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazurek MA, Simoneit BRT. 1986. Organic components in bulk and wet-only precipitation. CRC Crit Rev Environ Control 16:140.
McCall PJ. 1987. Hydrolysis of 1,3-dichloropropene in dilute aqueous solution. Pestic Sci 19:235–242.
Medinsky MA, Bond JA, Dutcher JS, . 1984. Disposition of [^14^C]2,3-dichloropropene in Fischer-344 rats after oral or intraperitoneal administration. Toxicol Lett 23:119–125.6485012
Meister RT, Sine C, Sharp DT, . 2006. 1,3-Dichloropropene. Crop protection handbook. Willoughby, OH: Meister Media Worldwide, D140, F34.
Meylan WM, Howard PH, Boethling RS, . 1999. Improved method for estimating bioconcentration/bioaccumulation factor from octanol/water partition coefficient. Environ Toxicol Chem 18(4):664–672.
Mizell M. 1988a. Telone C-17^®^ soil fungicide and nematicide: Primary dermal irritation study in New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516580.
Mizell M. 1988b. Telone C-17^®^ soil fungicide and nematicide: Dermal sensitization potential in the Hartley albino guinea pig. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516507.
Mizell M, Johnson K, Battjes J. 1988b. Telone C-17^®^ soil fungicide and nematicide: Acute dermal toxicity study in New Zealand white rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517368.
Mizell M, Yano BL, Battjes JE. 1988a. Telone C-17^®^ soil fungicide and nematicide: Acute oral toxicity study in Fischer 344 rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516595.
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Monsanto. 1967. Initial submission: Toxicological investigation of: 2,3-dichloropropene. St. Louis MO: Monsanto Agricultural Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0539077.
Moran MJ, Lapham WW, Rowe BL, . 2004. Volatile organic compounds in ground water from rural private wells, 1986 to 1999. J Am Water Resour Assoc 40(5):1141–1157.
Morita T, Asano N, Awogi T, . 1997a. Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (groups 1, 2A, and 2B) The summary report of the 6th collaborative study by CSGMT/JEMS MMS. (Erratum in: Mutat Res 391(3):259-267). Mutat Res 389:3–122.9062586
*Morita T, Asano N, Awogi T, . 1997b. Erratum to Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (Groups 1, 2A and 2B). The summary report of the 6th collaborative study by CSGMT/JEMS MMS’ [Mutat Res 389(1997) 3-122]. Mutat Res 391(3):259–267.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Munnecke DE, Vangundy SD. 1979. Movement of fumigants in soil, dosage, responses, and differential effects. Ann Rev Phytopathol 17:405–429.18393685
Myhr BC, Caspary WJ. 1991. Chemical mutagenesis at the thymidine kinase locus in L5178Y mouse lymphoma cells: Results for 31 coded compounds in the National Toxicology Program. Environ Mol Mutagen 18:51–83.1864269
NARA. 2006. Electronic Code of Federal Regulations. Washington, DC: National Archives and Records Administration. http://www.access.gpo.gov/nara/cfr/cfr-table-search.html. March 20, 2006.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nater JP, Gooskens VHJ. 1976. Occupational dermatosis due to a soil fumigant. Contact Dermatitis 2:227–229.139277
NCFA. 1997. NCFAP pesticide use database. Washington, DC: National Center for Food and Agricultural Policy. http://pestdata.ncsu.edu/ncfap/search.cfm. March 18, 2006.
NEMI. 1992. Method 524.2: Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. May 25, 2006.
NEMI. 1997a. Method 6200B: Volatile organic compounds in water by purge and trap capillary-column GC/MS method. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 05, 2006.
NEMI. 1997b. Method 6200C: Volatile organic compounds in water by purge and trap capillary- column GC method. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 05, 2006.
NEMI. 2001. Method D5790: Standard test method for measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 05, 2006.
Neudecker T, Henschler D. 1986. Mutagenicity of chloroolefins in the Salmonella/mammalian microsome test. III. Metabolic activation of the allylic chloropropenes allyl chloride, 1,3-dichloropropene, 2,3-dichloro-1-propene, 1,2,3-trichloropropene, 1,1,2,3-tetrachloro-2-propene and hexachloropropene by S9 mix via two different metabolic pathways. Mutat Res 170:1–9.3515164
Neudecker T, Dekant W, Jorns M, . 1986. Mutagenicity of chloroolefins in the Salmonella/mammalian microsome test - II. Structural requirements for the metabolic activation of non- allylic chloropropenes and methylated derivatives via epoxide formation. Biochem Pharmacol 35(2):195–200.3942595
Neudecker T, Lutz D, Eder E, . 1980. Structure-activity relationship in halogen and alkyl substituted allyl and allylic compounds: Corelation of alkylating and mutagenic properties. Biochem Pharmacol 29:2611–2617.7000076
Neudecker T, Stefani A, Henschler D. 1977. In vitro mutagenicity of the soil nematicide 1,3-dichloropropene. Experientia 33:1084–1085.330205
NIOSH. 2005. 1,3 Dichloropropene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 08, 2006.
NIOSH. 2006. 1,3-Dichloropropene. National occupational exposure survey (1981-1993). Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. http://www.cdc.gov/noes1/x3912sic.html. May 15, 2006.
Nishihara T, Nishikawa J, Kanayama T, . 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press, National Research Council.
NTP. 1985. Toxicology and carcinogenesis studies of Telone II^®^ (technical-grade 1,3-dichloropropene [CAS No. 542-75-6] containing 1.0% epichlorohydrin as a stabilizer) in F344/N rats and B6C3F1 mice (gavage studies). U.S. Department of Health and Human Services. National Toxicology Program. Technical Report Series 269. http://ntp.niehs.nih.gov/ntp/htdocs/LT_rpts/tr269.pdf. February 21, 2006.
NTP. 1989. Unfinished 13-week inhalation study on 2,3-dichloropropene (2,3-dichloropropylene; CASRN 78-88-6). (1989 data tables included). Research Triangle Park, NC: National Toxicology Program. U.S. Department of Health and Human Services.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntpserver.niehs.nih.gov/ntp/roc/eleventh/profiles/s067dich.pdf. January 11, 2008.
NTP. 2006. Written communications between Margaret E. Fransen, Ph.D., Syracuse Research Corporation, and National Toxicology Program about unfinished 13-week inhalation study on 2,3-dichloropropene (2,3-dichloropropylene; CASRN 78-88-6).
NTP. 2008. Testing Status: 1,3-Dichloropropene (Telone II) 10560-H. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp.niehs.nih.gov/index.cfm?objectid=BCC8C2FE-123F-7908-7B943C9BD3178BD9. November 25, 2008.
O’Neil MJ, Smith A, Heckelman PE, . eds. 2001. 1,3-Dichloropropene. Merck index. 13th ed. Whitehouse Station, NJ: Merck Research Laboratories, 541.
Onkenhout W, Mulder PP, Boogaard PJ, . 1986. Identification and quantitative determination of mercapturic acids formed from Z- and E-1,3-dichloropropene by the rat, using gas chromatography with three different detection techniques. Arch Toxicol 59(4):235–241.3827591
OSHA. 2005. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
Osterloh JD, Feldman BJ. 1993. Urinary protein markers in pesticide applicators during a chlorinated hydrocarbon exposure. Environ Res 63(2):171–181.8243412
Osterloh JD, Cohen B-S, Popendorf W, . 1984. Urinary excretion of the N-acetyl cysteine conjugate of cis-1,3-dichloropropene by exposed individuals. Arch Environ Health 39:271–275.6548620
Osterloh J, Letz G, Pond S, . 1983. An assessment of the potential testicular toxicity of 10 pesticides using the mouse-sperm morphology assay. Mutat Res 116:407–415.6835254
Osterloh JD, Wang R, O’Connell L, . 1989b. Pilot study for biological monitoring of 1,3-dichloropropene. In: Wang RG, Franklin CA, Honeycutt RC, . eds. American Chemical Society Symposium Series Chapter 17. Washington DC: American Chemical Society, 382, 215–230.
Osterloh JD, Wang R, Schneider F, . 1989a. Biological monitoring of dichloropropene: Air concentrations, urinary metabolite, and renal enzyme excretion. Arch Environ Health 44:207–213.2782944
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Int J Environ Anal Chem 31:41–53.
Ou L-T. 1989. Degradation of Telone II in contaminated and noncontaminated soils. J Environ Sci Health B 24(6):661–674.
Ou L-T. 1998. Enhanced degradation of the volatile fumigant-nematicides 1,3-D and methyl bromide in soil. J Nematol 30(1):56–64.19274199
Ou L-T, Chung K-Y, Thomas JE, . 1995. Degradation of 1,3-dichloropropene (1,3-D) in soils with different histories of field applications of 1,3-D. J Nematol 27(3):249–257.19277287
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pakdel H, Couture G, Roy C, . 1994. Developing methods for the analysis of toxic chemicals in soil and groundwater: The case of Ville Mercier, Quebec, Canada. In: Groundwater contamination and analysis at hazardous waste sites. New York, NY: Marcel Dekker, Inc., 381–421.
Pankow JF, Luo W, Bender DA, . 2003. Concentrations and co-occurrence correlations of 88 volatile organic compounds (VOCs) in the ambient air of 13 semi-rural to urban locations in the United States. Atmos Environ 37(36):5023–5046.
Pellizzari ED, Hartwell TD, Harris BSH, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pratt GC, Palmer K, Wu CY, . 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825.11017885
Roberts TR, Stoydin G. 1976. The degradation of (Z)- and (E)-1,3-dichloropropenes and 1,2-dichloropropane in soil. Pestic Science 7:325–335.
Roby DM, Melichar MW. 1997. 1,3-Dichloropropene regulatory issues. ACS Symp Ser 652:25–31.
Rogers SE, Peterson DL, Lauer WC. 1987. Organic contaminants removal for potable reuse. J Water Pollut Control Fed 59:722–732.
Rosenkranz HS, Klopman G. 1996. A study of the structural basis of the ability of chlorinated alkanes and alkenes to induce aneuploidy and toxicity in the mold Aspergillus nidulans. Mutat Res 354:183–193.8764947
RTECS. 2006. 1,3-Dichloropropene. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. April 05, 2006.
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leach contamination. Waste Management Res 2:119–130.
Sasaki YF, Saga A, Akasaka M, . 1998. Detection of in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419:13–20.9804871
Sasaki YF, Sakaguchi M, Yamada H, . 1994. Evaluation of micronucleus induction in mice by four organochlorine pesticides: 1,2-Dibromo-3-chloropropane, 1,3-dichloropropene, 1,2-dichloroethane, and nitrofen. Mamm Mutagen Study Group Commun 2:87–93.
Schenker M, McCurdy S. 1986. Pesticides, viruses and sunlight in the etiology of cancer among agricultural workers. In: Becker CE, Coye MJ, eds. Cancer prevention: Strategies in the workplace. Washington DC: Hemisphere Publishing Corporation, 29–37.
Schiffmann D, Eder E, Neudecker T, . 1983. Induction of unscheduled DNA synthesis in HeLa cells by allylic compounds. Cancer Lett 20:263–269.6627227
Schneider M, Quistad GB, Casida JE. 1998a. 1,3-Dichloropropene epoxides: Intermediates in bioactivation of the promutagen 1,3-dichloropropene. Chem Res Toxicol 11(10):1137–1134.9778309
Schneider M, Quistad GB, Casida JE. 1998b. N2,7-Bis(1-hydroxy-2-oxopropyl)2’-deoxyguanosine: Identical noncyclic adducts with 1,3-dichloropropene epoxides and methylglyoxal. Chem Res Toxicol 11(12):1536–1542.9860499
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington DC: American Physiological Society, 143–172.
Smelt JH, Teunissen W, Crum SJH, . 1989. Accelerated transformation of 1,3-dichloropropene in loamy soils. Neth J Agric Sci 37:173–183.
Smith MB, March J. 2001. March’s advanced organic chemistry reactions, mechanisms, and structure. New York, NY: John Wiley & Sons, 428, 433, 463.
Smyth HF, Carpenter CP, Weil CS, . 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23:95–107.13914538
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in waste waters and residuals from the petroleum refining industry. Environ Int 7:237–258.
Spicer CW, Buxton BE, Holdren MW, . 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30(20):3443–3456.
SRI. 2005. Pesticides: 1,3-Dichloropropene. Directory of chemical producers. Menlo Park, CA: Access Intelligence, LLC, 777.
Stebbins KE, Johnson KA, Jeffries TK, . 2000. Chronic toxicity and oncogenicity studies of ingested 1,3-dichloropropene in rats and mice. Regul Toxicol Pharmacol 32(1):1–13.11029263
Stebbins KE, Quast JF, Haut KT, . 1999. Subchronic and chronic toxicity of ingested 1,3-dichloropropene in dogs. Regul Toxicol Pharmacol 30(3):233–243.10620473
Sterrett RJ, Ransom ME, Barnhill GD. 1986. Site assessment and on-site treatment of a pesticide spill in the vadose zone. In: Proceedings of the Conference on Hazardous Material Spills, Preparedness, Prevention, Control, and Cleanup of Releases, Association of American Railroads, United States Coast Guard, St. Louis, MO May 5-8, 1986. Chemical Manufacturers Association, 84–92.
Stolzenberg SJ, Hine CH. 1980. Mutagenicity of 2- and 3-carbon halogenated compounds in the Salmonella/mammalian-microsome test. Environ Mutagen 2:59–66.7035158
Stott W, Kastl P. 1986. Inhalation pharmacokinetics of technical grade 1,3-dichloropropene in rats. Toxicol Appl Pharmacol 85:332–341.3764918
Stott W, Young J, Calhoun L, . 1988. Subchronic toxicity of inhaled technical grade 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 11:207–220.3220200
Stott WT, Gilbert JR, McGuirk RJ, . 1998. Bioavailability and pharmacokinetics of microencapsulated 1,3-dichloropropene in rats. Toxicol Sci 41(1):21–28.9520338
*Stott WT, Gollapudi BB, Rao KS. 2001. Mammalian toxicity of 1,3-dichloropropene. Rev Environ Contam Toxicol 168:1–42.12882226
*Stott WT, Waechter JM, Quast JT. 1990. Comment to the editors. Arch Environ Health 45(4):250–255.2400248
Streeter C, Lomax L. 1988. Telone C-17^®^ soil fungicide and nematocide: A one-hour acute vapor inhalation study in Fischer 344 rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517371.
Streeter C, Battjes J, Lomax L. 1987. Telone II^®^ soil fumigant: An acute vapor inhalation study in Fischer 344 rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517084.
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 300–301.
Suffet IH, Brenner L, Cairo PR. 1980. GC/MS identification of trace organics in Philadelphia drinking waters during a 2-year period. Water Res 14:853–867.
*Suzuki T, Komatsu M, Sasaki H, . 1995. Cytotoxicity of halogenated hydrocarbons and cellular phospholipid peroxidation in isolated rat hepatocytes. Jpn J Toxicol Environ Health (Eisei Kagaku) 41(1):35.
Suzuki T, Nezu K, Sasaki H, . 1994a. Cytotoxicity of chlorinated hydrocarbons and lipid peroxidation in isolated rat hepatocytes. Biol Pharm Bull 17(1):82–86.8148821
Suzuki T, Sasaki H, Komatsu M, . 1994b. Cytotoxicity of 1,3-dichloropropene and cellular phospholipid peroxidation in isolated rat hepatocytes, and its prevention by alpha-tocopherol. Biol Pharm Bull 17(10):1351–1354.7874057
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio and water solubility. Res Rev 85:17–28.
Tabak HH, Quave SA, Mashni CI, . 1981a. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tabak HH, Quave SA, Mashni CI, . 1981b. Biodegradability studies for predicting the environmental fate of organic priority pollutants. In: Test protocols for environmental fate and movement of toxicants. Symposium: 94th Annual Meeting of the Association of Official Analytical Chemists, Washington, DC. Arlington, VA: Association of Official Analytical Chemists, 267–328.
Talcott R, King J. 1984. Mutagenic impurities in 1,3-dichloropropene preparations. J Natl Cancer Inst 72:1113–1116.6585587
Thomas RG. 1982. Volatilization from water. In: Handbook of Chemical Property Estimation Methods: Environmental Behavior of Organic Compounds. Lyman WJ, Reehl WF, Rosenblatt DH, eds. Chapter 15. New York NY: McGraw Hill Book Co., 15-1-15-34
Thomas IJ, McKenry MV. 1974. Part I: Movement and fate as affected by various conditions in several soils. Hilgardia 42:393–421.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton NJ: Princeton Scientific Publishing, 365–394.
Til H, Spanjers T, Feron V, . 1973. Sub-chronic (90-day) toxicity study with Telone^®^ in albino rats (final report). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515831.
Tomlin CDS, ed. 2003. 1,3-Dichloropropene (233). In: e-Pesticide manual. 13th ed. United Kingdom: British Crop Protection Council.
Torkelson TR, Oyen F. 1977. The toxicity of 1,3-dichloropropene as determined by repeated exposure of laboratory animals. Am Ind Hyg Assoc J 38:217–223.868761
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 21, 2007.
Tu CM. 1988. Effects of selected pesticides on activities of invertase, amylase and microbial respiration in sandy soil. Chemosphere 17:159–163.
Tuazon EC, Atkinson R, Winer AM, . 1984. A study of the atmospheric reactions of 1,3-dichloropropene and other selected organochlorine compounds. Arch Environ Contam Toxicol 13:691–700.
Union Carbide Corp. 1958. Range finding tests on 2,3-dichloro-1-propene. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515587.
U.S. Army. 1985. Toxic chemicals in the soil environment. Vol. 2: Interactions of some toxic chemicals/chemical warfare agents and soils. Dugway, Utah: U.S. Army Dugway Proving Ground. ADA158215.
USGS. 1998. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory: Determination of 86 volatile organic compounds in water by gas chromatography/mass spectrometry, including detections less than reporting limits. Denver, CO: U.S. Geological Survey. Open file report 97–829.
USGS. 2001. Ground-water quality in the Cook Inlet Basin, Alaska, 1999. Anchorage, AK: U.S. Geological Survey. WRI Report 01–4208.
USGS. 2002. Quality of shallow ground water in areas of recent residential and commercial development, Wichita, Kansas, 2000. Lawrence, KS: U.S. Geological Survey, U.S. Department of the Interior. WRI Report 02-4228.
USITC. 1989. Synthetic organic chemicals, United States production and sales, 1988. Washington, DC: United States International Trade Commission. USITC Publication #2219.
Valencia R, Mason J, Woodruff R, . 1985. Chemical mutagenesis testing in Drosophila. III. Results of 48 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:325–348.3930234
van der Pas LJT, Leistra M. 1987. Movement and transformation of 1,3-dichloropropene in the soil of flower-bulb fields. Arch Environ Contam Toxicol 16:417–422.3606202
van Duuren B, Goldschmidt B, Loewengart G, . 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
van Joost T, de Jong G. 1988. Sensitization to DD soil fumigant during manufacture. Contact Dermatitis 18(5):307–308.2970939
van Welie RT, van Duyn P, Brouwer DH, . 1991a. Inhalation exposure to 1,3-dichloropropene in the Dutch flower-bulb culture. Part II. Biological monitoring by measurement of urinary excretion of two mercapturic acid metabolites. Arch Environ Contam Toxicol 20(1):6–12.1996911
van Welie RT, van Marrewijk CM, de Wolff FA, . 1991b. Thioether excretion in urine of applicators exposed to 1,3-dichloropropene: A comparison with urinary mercapturic acid excretion. Br J Ind Med 48:492–498.1854651
van Welie RTH, van Duyn P, Vermeulen NPE. 1989. Determination of two mercapturic acid metabolites of 1,3-dichloropropene in human urine with gas chromatography and sulphur-selective detection. J Chromatogr 496:463–471.2613848
*van Welie RTH, van Duyn P, Vermeulen NPE. 1991c. Environmental and biological monitoring of non-occupational exposure to 1,3-dichloropropene. Int Arch Occup Environ Health 63:169–173.1917066
Verberk MM, Brouwer DH, Brouwer EJ, . 1990. Health effects of pesticides in the flower-bulb culture in Holland. Med Lav 81(6):530–541.2100770
Verhagen C, Lebbink G, Bloem J. 1996. Enhanced biodegradation of the nematicides 1,3-dichloropropene and methyl isothiocyanate ina variety of soils. Soil Biol Biochem 12:1753–1756.
Verplanke AJ, Bloemen LJ, Brouwer EJ, . 2000. Occupational exposure to cis-1,3-dichloropropene: Biological effect monitoring of kidney and liver function. Occup Environ Med 57(11):745–751.11024198
Verschueren K, ed. 2001. 1,3-Dichloro-1-propene. Handbook of environmental data on organic chemicals. 4th ed. New York, NY: John Wiley & Sons, Inc., 810–811.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vithayathil AJ, McClure C, Myers JW. 1983. Salmonella/microsome multiple indicator mutagenicity test. Mutat Res 121:33–37.6346090
von der Hude W, Behm C, Guertler R, . 1988. Evaluation of the SOS Chromotest. Mutat Res 203:81–94.3280989
von der Hude W, Scheutwinkel M, Gramlich U, . 1987. Genotoxicity of three-carbon compounds evaluated in the SCE test in vitro. Environ Mutagen 9:401–410.3582297
Vos RM, van Welie RT, Peters WH, . 1991. Genetic deficiency of human class mu glutathione S-transferase isoenzymes in relation to the urinary excretion of the mercapturic acids of Z- and E-1,3-dichloropropene. Arch Toxicol 65(2):95–99.2059159
Vozza A, Ruocco V, Brenner S, . 1996. Contact pemphigus. Int J Dermatol 35(3):199–201.8655238
Waechter J, Kastl P. 1988. 1,3-Dichloropropene: Pharmacokinetics and metabolism in Fischer 344 rats following repeated oral administration. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516660.
Waechter JM, Brzak KA, McCarty LP, . 1992. 1,3-Dichloropropene (Telone II^®^soil fumigant): inhalation pharmacokinetics and metabolism in human volunteers (internal report). Dow Elanco. Submitted to the U.S. Environmental Protection Agency. MRID422903-01.
Wang GM. 1984. Evaluation of pesticides which pose carcinogenicity potential in animal testing. II. Consideration of human exposure conditions for regulatory decision making. Regul Toxicol Pharmacol 4(4):361–371.6084262
Wang D, Yates SR, Ernst FF, . 2001b. Volatilization of 1,3-dichloropropene under different application methods. Water Air Soil Pollut 127:109–123.
Wang Q, Gan J, Papiernik SK, . 2001a. Isomeric effects on thiosulfate transformation and detoxification of 1,3-dichloropropene. Environ Toxicol Chem 20(5):960–964.11337884
Watanabe K, Sakamoto K, Sasaki T. 1998. Comparisons on chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study II. Mutat Res 412:17–31.9508361
Watson W, Brooks T, Huckle K, . 1987. Microbial mutagenicity studies with (Z)-1,3-dichloropropene. Chem Biol Interact 61(1):17–30.3545509
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2^nd^ ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. 3^rd^ ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221:263–286.2682231
Winn RN, Norris MB, Lothenbach D, . 2006. Sub-chronic exposure to 1,1-dichloropropene induces frameshift mutations in λ transgenic medaka. Mutat Res 595:52–59.16337249
Wolford ST, Schroer RA, Gohs FX, . 1986. Reference range data base for serum chemistry and hematology values in laboratory animals. J Toxicol Environ Health 18:161–188.3712484
Yakel H, Kociba R. 1977. Acute inhalation toxicity of M-3993 (Telone II ^®^) in rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515858.
Yang R. 1986. 1,3-Dichloropropene. Residue Rev 97:19–35.3517997
Yon DA, Morrison GA, McGibbon AS. 1991. Dissipation of 1,3-dichloropropene in ditch bottom sediment and associated aerobic ditch water. Pestic Sci 32:147–159.
Zebarth BJ, Szeto SY, Hii B, . 1998. Groundwater contamination by chlorinated hydrocarbon impurities present in soil fumigant formulations. Water Qual Res J Can 33(1):31–50.
Zeiger E, Anderson B, Haworth S, . 1988. Salmonella mutagenicity tests: 4. Results from the testing of 300 chemicals. Environ Mol Mutagen 11:1–158.
Zempel JA, Grandjean M, Young JT. 1987. 2,3-Dichloropropene: Results of a two-week inhalation toxicity study in Fischer-344 rats and B6C3F1 mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000499-1.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372