# PEER REVIEW

A peer review panel was assembled in 2006 for dichloropropenes. The panel consisted of the following members:

1. Dr. Mary Davis, Professor, Department of Physiology and Pharmacology, West Virginia University Medical Center, Morgantown, West Virginia;
2. Dr. Rogene Henderson, Senior Scientist (retired), Lovelace Respiratory Research Institute, Alburquerque, New Mexico; and
3. Dr. Lisa M. Kamendulis, Assistant Professor, Department of Pharmacology and Toxicology, Indiana University School of Medicine, Indianapolis, Indiana.

These experts collectively have knowledge of 1,3-dichloropropene’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.