# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,1-, 1,2-, cis-1,3-, trans-1,3-, 2,3-, and 3,3-dichloropropene are listed in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,1-, 1,2-, cis-1,3-, trans-1,3-, 2,3-, and 3,3-dichloropropene are presented in Table 4-2.

Table 4-1 Chemical Identity of the Isomers of Dichloropropene

Characteristics | cis-1,3-Dichloro-propene | trans-1,3-Dichloro-propene | cis- and trans-1,3-Dichloro-propene | References | 1,1-Dichloropropene | 1,1-Dichloropropene | References | 2,3-Dichloropropene | 3,3-Dichloropropene | References
Chemical name | cis-1,3-Dichloro-propene | trans-1,3-Dichloro-propene | 1,3-Dichloropropene | Lide 2005; NIOSH 2005 | 1,1-Dichloropropene | 1,2-Dichloropropene | ChemID 2006c, 2006d; Lide 2005; RTECS 2006 | 2,3-Dichloropropene | 3,3-Dichloropropene | ChemID 2006e, 2006f; Lide 2005;
Synonyms | (Z)-1,3-Dichloro-propene; cis-1,3-dichloro-1-propene; dichlorocis-1,3-dichloro-propylene; cis-DCP | (E)-1,3-Dichloro-propene; trans-1,3-dichloro-1-propene; trans-1,3-dichloro-propylene; trans-DCP | 1,3-Dichloropropene; 1,3-dichloro-1-propene; 1,3-dichloro-propylene; 1,3-D | ChemID 2006a, 2006b | 1,1-Dichloro-1-propene; propene, 1,1-dichloro-; 1,1-dichloropropylene | Propene, 1,2-dichloro-; 1,2-dichloropropylene; propylene dichloride | ChemID 2006c, 2006d; RTECS 2006 | 2,3-Dichloro-1-propene;1.2-dichloro-2-propene; propene, 2,3-dichloro-;2.3-dichloropropylene | 1-Propene, 3,3-dichloro | ChemID 2006e, 2006f
Trade names | Not applicable | Not applicable | PIC CLOR; TRICAL; TRI-CAL TRILONE II; TRI-FORM; TELONE; INLINE | EPA 2006i | Not applicable | Not applicable | | Not applicable | Not applicable
Chemical formula | C_3_H_4_Cl_2_ | C_3_H_4_Cl_2_ | C_3_H_4_Cl_2_ | RTECS 2006 | C_3_H_4_Cl_2_ | C_3_H_4_Cl_2_ | RTECS 2006 | C_3_H_4_Cl_2_ | C_3_H_4_Cl_2_
Chemical structure | [image] | [image] | [image] | ChemID 2006a, 2006b; Lemen 2001; Lide 2005; | [image] | [image] | ChemID 2006e, 2006f | [image] | [image] | ChemID 2006e, 2006f
Identification numbers:
CAS registry | 10061-01-5 | 10061-02-6 | 542-75-6 | RTECS 2006 | 563-58-6 | 563-54-2 | RTECS 2006 | 78-88-6 | 563-57-5 | ChemID 2006e, 2006f
NIOSH RTECS | UC8325000 | UC8320000 | UC8310000 | RTECS 2006 | UC8290000 | UC8300000 | RTECS 2006 | UC8400000 | Not applicable | HSDB 2006
EPA hazardous waste | Not available | Not available | U084 | RTECS 2006 | Not available | Not available | RTECS 2006 | Not available | Not available
DOT/UN/NA/IMCO shipping | UN/DOT 2047; IMO 3.2 | UN/DOT 2047; IMO 3.2 | UN/DOT 2047; IMO 3.3 | DOT 2000; HSDB 2006 | UN/DOT 2047; IMO not available | UN/DOT 2047; IMO 3.3 | DOT 2000; HSDB 2006 | UN/DOT 2047; IMO 3.3 | UN/DOT 2047; IMO not available | DOT 2000
HSDB | 1503 | 1504 | 1109 | HSDB 2006 | Not applicable | 6175 | HSDB 2006 | 5222 | Not applicable | HSDB 2006
NCI | Not available | Not available | NCI-C03985 | HSDB 2006 | Not available | Not available | HSDB 2006 | Not available | Not available

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Consultative Organization; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of the Isomers of Dichloropropene

Property | cis-1,3-Dichloro-propene | trans-1,3-Dichloro-propene | cis- and trans-1,3-Dichloro-propene | References | 1,1-Dichloropropene | 1,2-Dichloropropene | References | 2,3-Dichloropropene | 3,3-Dichloropropene | References
Molecular weight | 110.97 | 110.97 | 110.97 | RTECS 2006 | 110.97 | 110.97 | RTECS 2006 | 110.97 | 110.97 | ChemID 2006e, 2006f; RTECS 2006
Color | Colorless | Colorless | Colorless to amber | Lewis 2001; | Not available | Not available | | Straw-colored | Not available | Verschueren 2001
Physical state | Liquid | Liquid | Liquid | Tomlin 2003 Lewis 2001; | Liquid | Liquid | EPA 1981c | Liquid | Liquid | EPA 1981c; Lide 2005
Melting point | Not available | Not available | −84 °C | Tomlin 2003 Verschueren 2001 | Not available | Not available | | 10 °C | Not available | Lide 2005; Verschueren 2001
Boiling point | 104.3 °C | 112.0 °C | 108 °C | O’Neil et al. 2001 | 76.5 °C | 75 °C | Lide 2005; Verschueren 2001 | 94 °C | 84.4 °C | EPA 1981c; Lide 2005
Density | 1.224 g/cm^3^ at 20 °C | 1.217 g/cm^3^ at 20 °C | 1.211 g/cm^3^ at 25 °C | Meister et al. 2006; O’Neil et al. 2001 | 1.186 g/cm^3^ at 25 °C | Not available | Lide 2005 | 1.211 g/cm^3^ at 20 °C | 1.224 g/cm^3^ at 20 °C | Lide 2005; Meister et al. 2006; O’Neil et al. 2001
Odor | Not available | Not available | Sweet, penetrating | Tomlin 2003 | Not available | Not available | | Pungent | Not available | Verschueren 2001
Odor threshold
Water | Not available | Not available | Not available | | Not available | Not available | | Not available | Not available
Air | Not available | Not available | 1 ppm | Verschueren 2001 | Not available | Not available | | Not available | Not available
Solubility
Water at 20 °C | 2.7×10^3^ mg/L | 2.8×10^3^ mg/L | 2.0×10^3^ mg/L | Dilling 1977; Tomlin 2003 | Not available | 2.7×10^3^ mg/L at 25 °C | Gunther et al. 1968 | 2.15×10^3^ mg/L at 25 °C | Not available | Mackay and Shiu 1981
Organic solvents | Soluble in ether, benzene, and chloroform | Soluble in ether, benzene, and chloroform | Miscible with hydrocarbons, halogenated solvents, esters, and ketones | Lide 2005; Tomlin 2003 | Soluble in ether, acetone, and chloroform | Soluble in ether, benzene, and chloroform | Lide 2005 | Miscible in ethanol, soluble in ether, benzene, and chloroform and chloroform | Soluble in ether, benzene, and chloroform | Lide 2005; Tomlin 2003
Partition coefficients
Log octanol/water | 2.06 | 2.03 | 1.82 | Tomlin 2003 | Not available | Not available | | Not available | Not available
K_oc_ | 23, 25.7, 26.3, 27.6 | 26, 27.8, 27.2, 27.5 | 18-60 | HamaKer and Thompson 1972; Kenaga 1980; Kim et al. 2003b | Not available | Not available | | Not available | Not available
Vapor pressure | 30 mm Hg at 20 °C | 22 mm Hg at 20 °C | 27.8 mm Hg at 20 °C | Dilling 1977; EPA 1981c | 91 mm Hg at 20 °C | 91 mm Hg at 20 °C | EPA 1981c | 45 mm Hg at 20 °C | 71 mm Hg at 20 °C | EPA 1981c
Vapor density (air = 1) | Not available | Not available | 3.83 | Lemen 2001 | Not available | 3.83 | Lewis 2000; Verschueren 2001 | 3.8 | Not available | Lewis 2000; Verschueren 2001
Henry’s law constant (atm/m^3^-molecule at 20 °C) | 2.71×10^−3^ | 8.71×10^−4^ | 3.55×10^−3^ | EPA 1987b; Leistra 1970 | Not available | Not available | | Not available | Not available
Flashpoint (open cup) | 21 °C (69.8 °F) | 21 °C (69.8 °F) | 35 °C (95 °F) | Lewis 2000, 2001 | Not available | Not available | | 10 °C (50 °F) | Not available | Lewis 2000
Conversion factors
ppm (v/v) to mg/m^3^ in air (20 °C) | 4.61 | 4.61 | 4.61 | Verschueren 2001 | 4.61 | 4.61 | Verschueren 2001 | 4.61 | 4.61 | Verschueren 2001
mg/m^3^ to ppm (v/v) in air (20 °C) | 0.22 | 0.22 | 0.22 | Verschueren 2001 | 0.22 | 0.22 | Verschueren 2001 | 0.22 | 0.22 | Verschueren 2001
Bioconcentration factor (log BCF) | Not available | Not available | Not available | | Not available | Not available | | Not available | Not available
Explosive limits | Not available | Not available | 5.3–14.5% | NIOSH 2005 | Not available | Not available | | Not available | Not available