# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## 2,3-Dichloropropene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichloropropene
CAS Numbers: | 78-88-6
Date: | June 2008
Profile Status: | Final Draft Post-public
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 3
Species: | Rat

[underlined: Minimal Risk Level]: 0.002 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Zempel JA, Grandjean M, Young JT. 1987. 2,3-Dichloropropene: Results of a two-week inhalation toxicity study in Fischer-344 rats and B6C3F1 mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000499-1 .

[underlined: Note]: The principal study is an unpublished study that has been peer reviewed.

[underlined: Experimental design]: Groups (five/sex/concentration) of B6C3F1 mice and F344 rats were exposed to vapors of 2,3-dichloropropene (>99% purity) 6 hours/day for nine exposures over 11 days at concentrations of 0, 5, 25, or 75 ppm (0, 22.7, 113.5, or 340 mg/m^3^). Animals were examined daily for signs of toxicity. Body weights were measured on days 1, 3, 5, and 12. Urine samples were collected from rats before the last exposure on day 11. At termination on day 12 after an overnight fast, blood samples were taken from rats and mice for hematology and serum chemistry analyses. All rats and mice received a complete necropsy examination that, for rats, included the eyes. Absolute and relative organ weights were recorded and calculated for brain, heart, liver, thymus, kidneys, and testes. All saved tissues were examined microscopically for all animals in the control and 75 ppm groups; in the 5 and 25 ppm groups, target tissues were examined for histopathology (liver, kidneys, bone marrow, lungs, and nasal tissues in both species, and also thymus, trachea, and larynx in mice). The study was conducted under Good Laboratory Practice standards.

[underlined: Effects noted in study and corresponding doses]: NOAELs were not identified in rats or mice. The lowest tested concentration, 5 ppm, was a LOAEL for respiratory lesions in both species.

Rats: Treatment caused no significant changes in survival, daily activities, or hematology, serum chemistry, or urinalysis results in rats. Statistically significant reductions in body weight in ≥25 ppm groups compared to controls were not biologically significant. Observed organ weight changes reflected changes in body weight and were not accompanied by histopathology. Histopathology of the respiratory tract was the major effect of exposure, showing concentration-related increases in severity. In all rats exposed at 25–75 ppm, slight-to-moderate degeneration (thinning) of the nasal olfactory epithelium was observed, secondarily producing inflammation and sloughing of necrotic cells. Hyperplasia of the nasal respiratory epithelium was observed in nearly all treated rats except for one male treated at 5 ppm: the severity of this lesion was very slight at ≥5 ppm, slight at 25 ppm, and moderate at 75 ppm (Table A-1). Slight peribronchiolar infiltration of eosinophils was observed in one male at 5 ppm and most rats at 25–75 ppm, but the study authors were uncertain as to the toxicological significance of this lesion. In male and female rats, 5 ppm was a LOAEL for hyperplasia of the nasal respiratory epithelium.

Table A-1 Incidence of Significant Lesions in Fischer 344 Rats and B6C3F1 Mice Exposed to 2,3-Dichloropropene (>99%) Vapor 6 Hours/Day, for 9/11 Days^a^

| Control | 5 ppm | 25 ppm | 75 ppm
Rats
Hyperplasia of nasal respiratory epithelium
Male | 0/5 | 4/5^*^ | 5/5^**^ | 5/5^***^
Female | 0/5 | 5/5^*^ | 5/5^**^ | 5/5^***^
Mice
Hyperplasia of nasal respiratory epithelium
Male | 0/5 | 3/5^*^ | 5/5^**^ | 5/5^***^
Female | 0/5 | 4/5^*^ | 5/5^**^ | 5/5^***^
Diffuse degeneration of bronchial/bronchiolar epithelium
Male | 0/5 | 5/5^**^ | 5/5^***^ | 5/5^****^
Female | 0/5 | 5/5^**^ | 3/5^***^+ 2/5^****^ | 5/5^****^

a Severity:

* very slight

** slight

*** moderate

**** severe

Source: Zempel et al. 1987

Mice: Treatment had no significant effect on survival in mice. Upon repeated exposure, reduced activity levels were observed in all groups in a concentration-related manner; beginning with the third exposure at 25 or 75 ppm, slow and labored respiration was observed during exposure on days 3 and 5. Food intake (as estimated by fecal output) appeared to be reduced in the 25 and 75 ppm groups during the first week. Body weights were significantly lower compared to controls by 12–25% in males and 16–26% in females exposed at 25 or 75 ppm. According to the study authors, hematology and serum chemistry changes indicated mild dehydration and stress-induced lymphopenia at ≥25 ppm rather than direct toxic effects of the compound (for example, increased ALT at 75 ppm was not accompanied by histology, but seemed to be a consequence of hemoconcentration). At gross necropsy, the size and weight of the thymus were reduced in male and female mice exposed at ≥25 ppm. Microscopic examination showed diffuse cortical atrophy of the thymus, which study authors considered secondary to stress, at 75 ppm. Histopathology of the respiratory tract was the most significant effect of exposure and showed concentration-related increases in severity (Table A-1). Slight-to-moderate degeneration of nasal olfactory epithelium was observed at ≥25 ppm and very slight-to moderate hyperplasia of the nasal respiratory mucosa occurred at ≥5 ppm. Hyperplasia (very slight-to-slight) of the laryngeal epithelium was observed at ≥25 ppm. In the bronchial/bronchiolar tissue, a diffuse degenerative lesion of the ciliated respiratory epithelium was slight at 5 ppm (irregular cells size and apical nuclei in many cells), moderate at 25 ppm and severe at 75 ppm, showing flattened or cuboidal epithelium (rather than columnar) with sparse ciliation and apical rather than basal nuclei. In male and female mice, 5 ppm was a LOAEL for very slight hyperplasia of the nasal respiratory epithelium and slight diffuse degeneration of the bronchial/bronchiolar epithelium.

[underlined: Dose and end point used for MRL derivation]: Very slight hyperplasia of nasal respiratory epithelium in female rats exposed to 5 ppm 2,3-dichloropropene (>99% purity), 6 hours/day, for 9/11 days. The effect is considered minimal because the severity of the lesion was characterized by the study authors as very slight. Using EPA (1994) dosimetric adjustments (see below), a regional gas dose ratio (RGDR_ET_) of 0.1143 for extrathoracic effects was applied to the duration-adjusted LOAEL of 1.25 ppm, resulting in a human equivalent concentration (LOAEL_HEC_) of. 0.1429 ppm, the point of departure for the MRL.

[ ] NOAEL [X] [LOAEL]_HEC_

[underlined: Uncertainty Factors used in MRL derivation]: 90 applied to the LOAEL_HEC_ of 0.1429 ppm

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans using dosimetric adjustments
- [X] 10 for human variability

0.1429 ppm / 90 = 0.0016 ppm , rounded to 0.002 ppm

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: EPA (1994) methods for calculating dosimetric adjustments across species for inhalation exposures were applied to data for nasal lesions, defined as extrathoracic (ET) effects, in rats and mice, and for bronchial and bronchiolar lesions, defined as trachiobronchial (TB) effects, in mice. Values used in these calculations and the calculated regional gas dose ratios are given in Table A-2.

Table A-2 Values Used for Calculating Human Equivalent Concentrations to LOAELs of 5 ppm for Fischer F344 Rats and B6C3F1 Mice Exposed 6 Hours/Day, 9/11 Days to 2,3-Dichloropropene^a^

| Human | Rats | | Mice
| Human | Male | Female | Male | Female
Intercept b_0_^b^ | | −0.578 | −0.578 | 0.326 | 0.326
Slope b_1_^b^ | | 0.821 | 0.821 | 1.050 | 1.050
Time-weighted-average body weight^c^ (kg) | | 0.2326 kg | 0.1502 kg | 0.0254 kg | 0.0211 kg
VE (minute volume) (mL/minute) | 13,800^b^ | 169.42 | 118.3106 | 29.2857 | 24.1033
SA_ET_ (surface area of extra-thoracic region)^b^ | 200 cm^2^ | 15 cm^2^ | 15 cm^2^ | 3 cm^2^ | 3 cm^2^
RGDR _ET_ | | 0.1637 | 0.1143 | 0.1415 | 0.1164
(LOAEL-adjusted)_HEC-ET_ (ppm) | | 0.2046 | 0.1429 | 0.1769 | 0.1455
SA_TB_ (surface area of tracheo-bronchial region)^b^ | 3,200 cm^2^ | Not applicable | Not applicable | 3.5 cm^2^ | 3.5 cm^2^
RGDR _TB_ | | Not applicable | Not applicable | 1.7771 | 1.4305
(LOAEL-adjusted)_HEC-TB_ ppm | | Not applicable | Not applicable | 2.2214 | 1.7881

a Zempel et al. (1987)

b EPA (1994)

c Calculated from data in Zempel et al. (1987)

Although 2,3-dichloropropene is a category 2 gas, the extrathoracic (ET) regional gas dose ratios (RGDRs) were calculated from rat and mouse data using the equation for a category 1 gas by default, since an equation is not available for category 2 gases (EPA 1994).

RGDR_ET_ = (RGD_ET_)_rodent_ / (RGD_ET_)_human_ = (VE / SA_ET_)_rodent_ / (VE / SA_ET_)_human_

The tracheobronchial (TB) regional gas dose ratios were calculated from mouse data using the equation for a category 1 gas by default.

RGDR_TB_ = (RGD_TB_)_mouse_ / (RGD_TB_)_human_ = [(VE / SA_TB_)_mouse_ / (VE / SA_TB_)_human_] [(e^− [SAet / VE]_mouse_^) / (e^− [SAet / VE]_human_^)]

Where:

VE = minute volume in mL/minute

SA = surface area in cm^2^

The minute volumes (VE) for male and female rats and mice were calculated using the equation LN (VE) = b_0_ + b_1_ [LN (BW in kg)].

Slopes and intercepts for rats and mice were taken from EPA (1994). The acute time-weighted-average body weights for male and female B6C3F1 mice, and male and female Fischer 344 rats, were calculated from data reported in the key study. Values for calculating minute volumes are in Table A-2.

The calculated regional gas dose ratios for extrathoracic effects in rats and mice and tracheobronchial effects in mice (Table A-2) were applied to the common duration-adjusted LOAEL of 1.25 ppm. The lowest human equivalent concentration was 0.1429 ppm for extrathoracic effects (hyperplasia of nasal respiratory epithelium) in female rats, which was selected as the point of departure for calculating the MRL since it would be protective against all effects.

Although a NOAEL was not available in this study, benchmark dose modeling was not performed to estimate an exposure level without appreciable risk because the data were not suitable. The group sizes were too small to model data sets for each sex separately, and the dose-response data for the combined sets provided no information as to the shape of the response curve below the tested exposure levels incidences for rats or mice with respiratory tract lesions increased from 0/10 in the control to 70–100% in the lowest exposure groups (Table A-1). For these reasons, the MRL was calculated using the NOAEL/LOAEL approach.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The LOAEL, 5 ppm, was adjusted for intermittent exposure (6 hours/24 hours), resulting in a duration-adjusted LOAEL of 1.25 ppm.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No data were available for the acute-duration inhalation toxicity of 2,3-dichloropropene in humans, and acute-duration inhalation data for animals, aside from the principal study, are limited to lethality studies (Dietz et al. 1985b; Monsanto 1967; Smyth et al. 1962; Union Carbide Corp. 1958). Exposure to an unquantified concentrated vapor of 2,3-dichloropropene resulted in effects on the eye (closure of eyelids, lacrimation), respiratory system (gasping, labored breathing, nasal discharge and, at necropsy, hemorrhagic lungs and inflammation of the nasal mucosa) and central nervous system (reduced activity, unconsciousness), and death within 30 minutes in rats (Monsanto 1967). An acute lethality inhalation study in rats reported no mortality at 250 ppm, 50% mortality at 500 ppm, and 100% mortality at 1,000 ppm after a 4-hour exposure (Smyth et al. 1962; Union Carbide Corp. 1958); this study provided no information about target organ specificity. In a 1-hour acute inhalation lethality study (for which even-numbered pages were missing), all rats exhibited irritant effects on the eye (lacrimation), respiratory tract (gasping, shallow respiration), gastrointestinal system (diarrhea), and central nervous system (lethargy) during exposure at concentrations of 693–1,963 ppm (Dietz et al. 1985b); postexposure lethargy and labored respiration were observed in rats exposed at 1,963 ppm. As described in Dietz et al. (1985b), results of a 6-hour range-finding inhalation study in rats included no overt toxicity at 75 ppm, crusted noses at 250 ppm, and bloody noses, diarrhea, lethargy, and death at 500 ppm; irritation of the eyes and nose were named as the primary treatment-related effects in the range-finding study.

The limited database indicates that irritant effects, especially on the respiratory system, are the critical effects of acute-duration inhalation exposure to 2,3-dichloropropene. The study by Zempel et al. (1987) was selected as the principal study since it was adequately designed and reported, and it documented respiratory effects at the lowest tested concentration in rats and mice, providing reliable LOAELs for these effects.

[underlined: Agency Contacts (Chemical Managers)]: Annette Ashizawa, Sharon Wilbur, and Heraline Hicks

## 1,3-Dichloropropene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,3-Dichloropropene
CAS Numbers: | 542-75-6
Date: | June 2008
Profile Status: | Final Draft Post-public
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 20
Species: | Mouse

[underlined: Minimal Risk Level]: 0.008 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Lomax L, Stott W, Johnson K, . 1989. The chronic toxicity and oncogenicity of inhaled technical grade 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 12:418–431 2731657 .

[underlined: Experimental design]: Groups (10/sex/concentration) of B6C3F1 mice and F344 rats were exposed to vapors of 1,3-dichloropropene 6 hours/day, 5 days/week for 6 months at concentrations of 0, 5, 20, or 60 ppm (0, 22.7, 90.8, or 272 mg/m^3^). These were designed as interim satellite groups for a 2-year study. The test material was 92.1% pure (49.5% cis; 42.6% trans) and contained 2.0% epoxidized soybean oil (ESO) as a stabilizer, 0.7% 1,2-dichloropropane, and a calculated 5.2% mixtures of hexanes and hexadienes. Animals were observed after each exposure for clinical signs and moribund animals necropsied to minimize postmortem autolysis. Body weights were recorded before the study began, weekly for the first 13 weeks, and at monthly intervals thereafter. Urinalysis was conducted on rats during the week prior to termination; hematology and clinical chemistry parameters were analyzed in blood samples taken from rats and mice at the time of necropsy. All animals received examination by gross necropsy, at which time absolute and relative brain, heart, kidney, liver, and testicular weights were recorded. More than 40 tissues, in addition to gross lesions, were examined for histopathology in control and high-exposure animals at scheduled sacrifice and in all animals dying prematurely. About 17 tissues, in addition to gross lesions, were examined in low- and mid-exposure animals at scheduled termination.

[underlined: Effects noted in study and corresponding doses]: Exposure to 1,3-dichloropropene for 6 months had no adverse effect on survival, clinical signs, or hematological or clinical chemistry parameters in mice. Body weights of high-dose mice were depressed compared to controls, but the differences were not biologically significant at 6 months. Reductions in liver and kidney weights in males at 60 ppm were attributed by study authors to the reduced body weight and were not accompanied by histopathology. Statistically significant increased incidences of histopathological lesions were observed in mice treated at 60 ppm: hypertrophy/hyperplasia of the nasal respiratory epithelium in male and female mice and hyperplasia of the urinary bladder in female mice (Table A-3).

Table A-3 Incidence of Significant Lesions in B6C3F1 Mice Exposed to 1,3-Dichloropropene (92.1%) Vapor 6 Hours/Day, 5 Days/Week for 6 Months

| Control | 22.7 mg/m^3^ (5 ppm) | 90.8 mg/m^3^ (20 ppm) | 272 mg/m^3^ (60 ppm)
Slight hypertrophy/hyperplasia of nasal respiratory epithelium
Male | 1/10 | 0/10 | 3/10 | 10/10^a^
Female | 0/10 | 0/10 | 0/10 | 7/10^a^
Hyperplasia of urinary bladder
Male | 0/10 | 0/10 | 0/10 | 1/10
Female | 0/10 | 0/10 | 0/10 | 4/10^a^

a Different from control using Fisher Exact Test

Source: Lomax et al. 1989

[underlined: Dose and end point used for MRL derivation]: Hypertrophy/hyperplasia of nasal respiratory epithelium in male and female B6C3F1 mice exposed to 60 ppm (272 mg/m^3^) 1,3-dichloropropene (92.1% purity), 6 hours/day, 5 days/week for 6 months was selected as the critical effect. Using benchmark concentration analysis, a BMCL_10_ value of 1.0678 mg/m^3^ was calculated for male mice and 13.5227 mg/m^3^ was calculated for female mice (see Tables A-4 and A-6). Using EPA (1994) dosimetric adjustments, the male BMCL_10_ value was converted to a human equivalent concentration ([BMCL_10_]_HEC_) of 1.0678 mg/m^3^ (0.2349 ppm), which was selected as the point of departure for the MRL since it was lower than the female value. Note that concentrations in mg/m^3^ were converted to ppm by using a factor of 0.22 (see Table 4-2 in this profile).

[ ] NOAEL [ ] LOAEL

[X] [BMCL_10_]

[underlined: Uncertainty Factors used in MRL derivation]: 30 applied to the [BMCL_0_]_HEC_ of 0.2349 ppm for nasal effects in male mice

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans using dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Although 1,3-dichloropropene is a category 2 gas, the extrathoracic (ET) regional gas dose ratios (RGDRs) were calculated from rat and mouse data using the equation for a category 1 gas by default, since an equation is not available for category 2 gases. This is equation 4-18 in EPA (1994); in this section, all pages/equations/tables refer to EPA (1994).

RGDR_ET_ = (Dose_ET_)_mouse_ / (Dose_ET_)_human_ = (VE / SA_ET_)_mouse_ / (VE / SA_ET_)_human_

The minute volumes (VE) for male and female mice were calculated using equation 4-4.

LN (VE) = b_0_ + b_1_ [LN (BW in kg)]

Intercept b_0_ of 0.326 and slope b_1_ of 1.050 for mouse were taken from Table A-6.

The subchronic body weights of 0.0316 kg for male and 0.0246 kg for female B6C3F1 mice were taken from Table 4-5.

VE_mouse_ | = mouse minute volume (L/minute) | = 36.8353 mL/minute for male mice and 28.3168 mL/minute for females.
(SA_ET_)_mouse_ | = mouse surface area of extrathoracic region | = 3 cm^3^, from Table A-4
VE_human_ | = human minute volume (L/minute) | = 13,800 mL/minute, from page 4-33
(SA_ET_)_human_ | = human surface area of extrathoracic region | = 200 cm^3^, from Table A-4

Extrathoracic regional gas dose ratios were calculated as 0.1779 for male mice and 0.1368 for females exposed in an intermediate-duration study. These values were used to convert the respective male and female mouse BMCL values to human equivalent concentrations (see below).

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The exposure concentrations (in mg/m^3^ as reported by study authors) were adjusted by the purity of the compound (92.1%) and intermittent exposure (6 hours/24 hours x 5 days/7 days). Benchmark concentration analyses were conducted using these adjusted exposure levels.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In the only intermediate-duration inhalation study in humans, no evidence of renal or hepatic damage was detected in clinical chemistry analyses of blood and serum in pesticide applicators using cis-1,3-dichloropropene for an average of 521 (±230) minutes/day at a geometric mean concentration (8-hour TWA) of 2.7 mg/m^3^ (range 0.1–9.5 mg/m^3^) (0.594 [0.22–2.09] ppm) over a 117-day period compared to unexposed controls (Verplanke et al. 2000). No other end points were examined in this study. Respiratory effects (mucous membrane irritation, chest pain, cough, and breathing difficulties) have been observed following accidental acute exposure to high concentrations (Flessel et al. 1978; Markovitz and Crosby 1984).

The available data from the inhalation exposure animal studies indicate that hypertrophy/hyperplasia of the nasal respiratory epithelium and hyperplasia of the urinary bladder in mice are the most sensitive effects associated with intermediate-duration exposed to 1,3-dichloropropene. Increased incidences of hypertrophy/hyperplasia of the nasal respiratory epithelium occurred in male and female B6C3F1 mice exposed to 60 ppm Telone II^®^b (92.1% 1,3-dichloropropene with 2% epoxidized soybean oil) vapor 6 hours/day, 5 days/week for 6 months (Lomax et al. 1989). Female mice in this study exposed at 60 ppm also had a marginally increased incidence of hyperplasia of the urinary bladder. Fischer 344 rats exposed in this study under the same protocol did not exhibit histopathology after 6 months exposure (Lomax et al. 1989). Slight reductions in body weights were observed in rats and mice exposed at 60 ppm, but the differences were not biologically significant (were <10% lower than controls) at 6 months (Lomax et al. 1989). Nasal lesions were also observed in rats exposed to ≥90 ppm Telone II^®^b 6 hours/day, 5–7 days/week for 3 months in a reproductive toxicity assay (Breslin et al. 1989). Nasal hyperplasia in rats and mice and urinary bladder hyperplasia in mice occurred in groups exposed to ≥90 ppm Telone II^®^a (90.9% 1,3-dichloropropene with 1.2% epichlorohydrin) 6 hours/day, 5 days/week for 13 weeks (Stott et al. 1988). One 13-week study by Coate (1979a) reported nasal lesions in rats exposed 6 hours/day, 5 days/week to Telone II^®^a at 30 ppm, but since the purity of the test material was not reported, the significance of the result is uncertain.

Although increased incidences of hypertrophy/hyperplasia of the nasal respiratory epithelium and hyperplasia of the urinary bladder were both sensitive effects in mice at a LOAEL of 60 ppm, urinary hyperplasia was only observed in females and at a marginal increase (p=0.043; Fisher Exact Test) over controls. Since the nasal lesions were observed in both sexes at a higher incidence, they were selected as the critical effect for development of the intermediate-duration MRL for 1,3-dichloropropene. The 6-month study with male and female mice exposed to Telone II^®^b by Lomax et al. (1989) was selected as the principal study because the study was adequately designed and reported, and because the test material contained a relatively high concentration of 1,3-dichloropropene without the confounding presence of epichlorohydrin or chloropicrin.

Potential points of departure for deriving the intermediate-duration MRL, derived with benchmark dose (concentration) analysis, are shown in Table A-4. Before the analysis, exposure concentrations in ppm were converted to mg/m^3^ and adjusted for 92.1% purity and discontinuous exposure. Additional details of the benchmark dose (concentration) analysis are described below.

For increased incidence of hypertrophy/hyperplasia of nasal epithelium in male and female mice, the potential point of departure was the BMCL associated with 10% extra risk; this BMR is the default recommended in EPA (2000a).

Table A-4 Potential Points of Departure for Determining the Intermediateduration Inhalation MRL for 1,3-Dichloropropene

End point | BMC^a^ (mg/m^3^) | BMCL^a^ (mg/m^3^)
Increased incidence of hypertrophy/hyperplasia of nasal respiratory epithelium in male and female mice exposed to Telone II^®^b vapor 6 hours/day, 5 days/week for 6 months | M 12.6179; F 28.7185 | M 6.0022; F 13.5227
BMR = 10% extra risk

a Adjusted for <100% purity and discontinuous exposure; To convert to ppm, multiply by 0.22

BMC = benchmark concentration; BMCL = 95% lower confidence limit for the benchmark concentration; BMR = benchmark response level; F = female; M = male; MRL = Minimal Risk Level

Source: Lomax et al. 1989

The mouse BMCL_10_ values were multiplied by the extrathoracic regional dose ratios (mouse/human) (calculated above) for male and female B6C3F1 mice. The male BMCL_20_ of 6.0022 mg/m^3^ for hypertrophy/hyperplasia of nasal respiratory epithelium multiplied by an RGDR of 0.1779 results in a human equivalent concentration of 1.0678 mg/m^3^ (0.2349 ppm). The female BMCL_10_ of 13.5227 mg/m^3^ for the same lesion multiplied by an RGDR of 0.1368 results in a human equivalent concentration of 1.8499 mg/m^3^ (0.407 ppm). The lower value based on male mice was selected as the point of departure for MRL derivation because it would be more protective of human health. A total uncertainty factor of 30 was applied to the male [BMCL_10_]_HEC_ of 0.2349 ppm to calculate the intermediate-duration inhalation MRL for 1,3-dichloropropene.

The intermediate-duration inhalation MRL for 1,3-dichloropropene is based on the Lomax et al. (1989) study which used technical grade dichloropropene containing 92.1% 1,3-dichloropropene, 0.7% 1,2-dichloropropene, 2% epoxidized soybean oil as a stabilizer, and a calculated 5.2% mixture of hexanes and hexadienes. It is unlikely that hexane significantly contributed to the toxicity of 1,3-dichloropropene. Although hexane and 1,3-dichloropropene both affect the olfactory epithelium, the lowest LOAEL for this effect by n-hexane is almost 2 orders of magnitude higher than for 1,3-dichloropropene. As such, the hexane and hexadiene component is not considered to be a confounder in toxicity assessments for 1,3-dichloropropene.

#### Details of Benchmark Dose Analysis for the Intermediate-duration Inhalation MRL

##### Male and Female Mice

All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for hypertrophy/hyperplasia of nasal respiratory epithelium in male and female B6C3F1 mice exposed to 1,3-dichloropropene via inhalation for 6 months (Table A-5). Predicted concentrations associated with 10, 5, and 1% extra risks were calculated.

Table A-5 Incidence of Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Male and Female B6C3F1 Mice Exposed 6 months, Adjusted for Purity and Discontinuous Exposure Administered concentration Adjusted for 92.1% Adjusted for discontinuous Incidence

Administered concentration | | Adjusted for 92.1% purity (mg/m^3^) | Adjusted for discontinuous exposure and rounded (mg/m^3^) | Incidence
ppm | mg/m^3^ | Adjusted for 92.1% purity (mg/m^3^) | Adjusted for discontinuous exposure and rounded (mg/m^3^) | Males | Females
0 | 0 | 0 | 0 | 1/10 | 0/10
5 | 22.7 | 20.9067 | 3.7 | 0/10 | 0/10
20 | 90.8 | 83.6268 | 14.9 | 3/10 | 0/10
60 | 272 | 250.512 | 44.7 | 10/10 | 7/10

Source: Lomax et al. 1989

##### Hypertrophy/hyperplasia of nasal respiratory epithelium in male and female mice

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data (x^2^ p-value ≥0.1) for the incidence of hypertrophy/hyperplasia of nasal respiratory epithelium in male (Table A-6) and female (Table A-7) B6C3F1 mice. Comparing across models, a better fit is indicated by a lower Akaike’s Information Criteria value (AIC) (EPA 2000b). The gamma model was determined to be the best-fitting model for both males and females, as indicated by the AIC (Tables A-6 and A-7; Figures A-1 and A-2). Benchmark concentrations (BMCs and BMCLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting model, are shown in Table A-8.

Table A-6 Goodness of Fit Statistics and BMC_10_s and BMCL_10_s from Models Fit to Incidence Data for Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Male B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 6 Months

Model | AIC | X^2^ p-value^a^ | BMC_10_ (mg/m^3^)^b^ | BMCL_10_ (mg/m^3^)^b^
Gamma ^c^ | 24.1579 | 0.5908 | 12.6179 | 6.00215
Logistic | 25.1526 | 0.3291 | 8.41841 | 5.1448
Log-Logistic | 26.1579 | 0.3049 | 13.939 | 7.23456
Multistage | 25.3494 | 0.4014 | 7.62026 | 3.9162
Probit | 25.2768 | 0.3167 | 7.64022 | 4.69897
Log-probit | 26.1579 | 0.3049 | 13.2999 | 6.97026
Quantal-linear | 31.8559 | 0.0529 | 2.70925 | 1.64437
Quantal-quadratic | 25.3494 | 0.4014 | 7.62026 | 5.43757
Weibull | 26.1579 | 0.3049 | 13.1405 | 5.44413

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b To convert to ppm, multiply by 0.22.

c Best-fitting model

AIC = Akaike’s Information Criteria; BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; p = p-value from the Chi-squared test

Source: Lomax et al. 1989

Figure A-1 Observed and Predicted Incidences of Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Male B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 6 Months^*^ * BMCs and BMCLs indicated are for a 10% extra risk and are in units of mg/m^3^.

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration

Source: Lomax et al. 1989

The form and parameters of the gamma model for the male mouse data are as follows:

P [response] = background + (1 − background) * CumGamma [slope * dose , power] ,

where CumGamma(.) is the cumulative Gamma distribution function

background | = | 0.0499995
slope | = | 1.01615
power | = | 18

Table A-7 Goodness of Fit Statistics and BMC_10_s and BMCL_10_s from Models Fit to Incidence Data for Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 6 Months

Model | AIC | X^2^ p-value^a^ | BMC_10_ (mg/m^3^)^b^ | BMCL_10_ (mg/m^3^)^b^
Gamma ^c^ | 14.2213 | 1.0000 | 28.7185 | 13.5227
Logistic | 16.2173 | 1.0000 | 40.0892 | 17.7767
Log-Logistic | 16.2173 | 1.0000 | 37.7164 | 13.5983
Multistage | 16.779 | 0.6925 | 14.6277 | 8.36083
Probit | 16.2173 | 1.0000 | 35.9801 | 16.19
Log-probit | 16.2173 | 1.0000 | 32.4372 | 13.6137
Quantal-linear | 21.6296 | 0.1851 | 6.90725 | 3.87399
Quantal-quadratic | 16.779 | 0.6925 | 14.6277 | 10.8645
Weibull | 16.2173 | 1.0000 | 38.8344 | 13.5533

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b To convert to ppm, multiply by 0.22.

c Best-fitting model

AIC = Akaike’s Information Criteria; BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; p = p-value from the Chi-squared test

Source: Lomax et al. 1989

Figure A-2 Observed and Predicted Incidences of Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 6 Months^*^ * BMCs and BMCLs indicated are for a 10% extra risk and are in units of mg/m^3^.

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration

Source: Lomax et al. 1989

The form and parameters of the gamma model for the female mouse data are as follows:

P [response] = background + (1 − background) * CumGamma [slope * dose , power] ,

where CumGamma(.) is the cumulative Gamma distribution function

background | = | 0
slope | = | 0.446459
power | = | 18

Table A-8 Best-fitting Model Predictions for 1, 5, and 10% Extra Risk for Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Male and Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 6 Months

Best fitting model | BMR (percent extra risk) | BMC (mg/m^3^)^a^ | BMCL (mg/m^3^)^a^
Male mice
Gamma | 1 | 9.46353 | 1.96448
Gamma | 5 | 11.4494 | 4.23342
Gamma | 10^b^ | 12.6179 | 6.00215
Female mice
Gamma | 1 | 21.5391 | 5.06945
Gamma | 5 | 26.059 | 9.93499
Gamma | 10 | 28.7185 | 13.5227

a To convert to ppm, multiply by 0.22.

b Best-fitting model

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; BMR = benchmark response

Source: Lomax et al. 1989

[underlined: Agency Contacts (Chemical Managers)]: Annette Ashizawa, Sharon Wilbur, and Heraline Hicks

## 1,3-Dichloropropene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,3-Dichloropropene
CAS Numbers: | 542-75-6
Date: | June 2008
Profile Status: | Final Draft Post-public
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 44
Species: | Mouse

[underlined: Minimal Risk Level]: 0.007 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Lomax L, Stott W, Johnson K, . 1989. The chronic toxicity and oncogenicity of inhaled technical grade 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 12:418–431 2731657 .

[underlined: Experimental design]: Groups (50/sex/concentration) of B6C3F1 mice and F344 rats were exposed to vapors of 1,3-dichloropropene 6 hours/day, 5 days/week for 2 years at concentrations of 0, 5, 20, or 60 ppm (0, 22.7, 90.8, or 272 mg/m^3^). Additional satellite groups (10/sex/concentration) were established interim sacrifices at 6 and 12 months (results for the 6-month sacrifice are given under the description for the intermediate-duration inhalation MRL). The test material was 92.1% pure 1,3-dichloropropene (49.5% cis; 42.6% trans) and contained 2.0% ESO as a stabilizer, 0.7% 1,2-dichloropropane, and calculated 5.2% mixtures of hexanes and hexadienes. Animals were observed after each exposure for clinical signs, and moribund animals necropsied to minimize postmortem autolysis. Body weights were recorded before the study began, weekly for the first 13 weeks, and at monthly intervals thereafter. Urinalysis was conducted on rats during the week prior to termination; hematology and clinical chemistry parameters were analyzed in blood samples taken from rats and mice at the time of necropsy. All animals received examination by gross necropsy, at which time absolute and relative brain, heart, kidney, liver, and testicular weights were recorded. More than 40 tissues, in addition to gross lesions, were examined for histopathology in control and high-exposure animals at scheduled sacrifice and in all animals dying prematurely. About 17 tissues, in addition to gross lesions, were examined in low- and mid-exposure animals at scheduled termination.

[underlined: Effects noted in study and corresponding doses]: Exposure to Telone II^®^b vapor for 2 years had no significant adverse effect on survival, body weight, the incidence of clinical signs, hematology, or clinical chemistry parameters in mice. In the 1-year satellite group, incidences of hypertrophy/hyperplasia of the nasal respiratory epithelium were significantly higher than controls in males at ≥20 ppm and in females at 60 ppm; females at 60 ppm also had increased incidences of epithelial hyperplasia and inflammation of the urinary bladder. Significant lesions observed in mice after 2 years of exposure are given in Table A-9. Nasal and urinary bladder lesions were elevated in males at 60 ppm and in females at ≥20 ppm. Increases in inflammation of the urinary bladder were not observed in males and were relatively small in females. Degeneration of the nasal olfactory epithelium was not statistically elevated in either sex at concentrations lower than 60 ppm. Hypertrophy/hyperplasia of the nasal respiratory epithelium and epithelial hyperplasia of the urinary bladder in females at ≥20 ppm were the most sensitive effects in this study.

Table A-9 Incidence of Significant Lesions in B6C3F1 Mice Exposed to 1,3-Dichloropropene (92.1%) Vapor 6 Hours/Day, 5 Days/Week for 2 Years

| Control | 22.7 mg/m^3^ (5 ppm) | 90.8 mg/m^3^ (20 ppm) | 272 mg/m^3^ (60 ppm)
Hypertrophy/hyperplasia of nasal respiratory epithelium (slight)
Male | 5/50 | 1/50 | 4/50 | 48/50^a^
Female | 4/50 | 4/50 | 28/50^a^ | 49/50^a^
Degeneration of nasal olfactory epithelium (slight)
Male | 1/50 | 0/50 | 1/50 | 48/50^a^
Female | 0/50 | 0/50 | 1/50 | 45/50^a^
Hyperplasia of urinary bladder (slight-moderate)
Male | 4/48 | 7/48 | 11/48 | 37/47^a^
Female | 1/47 | 4/46 | 21/48^a^ | 44/45^a^
Inflammation of urinary bladder (slight-severe)
Male | 0/48 | 0/48 | 0/48 | 2/47
Female | 0/47 | 1/46 | 6/48^a^ | 8/45^a^

a Statistically different from control

Source: Lomax et al. 1989

[underlined: Dose and end point used for MRL derivation]: Hypertrophy/hyperplasia of nasal respiratory epithelium in female B6C3F1 mice exposed at a LOAEL of 20 ppm (272 mg/m^3^) 1,3-dichloropropene (92.1% purity), 6 hours/day, 5 days/week for 2 years. Using benchmark concentration analysis, BMCL_10_ value of 4.5673 mg/m^3^ was calculated (see Tables A-10 and A-15), and a human equivalent concentration ([BMCL_10_]_HEC_) of 0.9130 mg/m^3^ (0.2009 ppm) was calculated using EPA (1994) dosimetric adjustments. Note that concentrations in mg/m^3^ were converted to ppm by using a factor of 0.22 (see Table 4-2 in this profile).

[ ] NOAEL [ ] LOAEL

[X] [BMCL_10_]

[underlined: Uncertainty Factors used in MRL derivation]: 30 applied to the [BMCL_10_]_HEC_ of 0.2009 ppm for nasal effects in female B6C3F1 mice

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

0.2009 ppm / 30 = 0.0067 , rounded to 0.007 ppm

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Although 1,3-dichloropropene is a category 2 gas, the extrathoracic (ET) regional gas dose ratios (RGDRs) were calculated from rat and mouse data using the equation for a category 1 gas by default, since an equation is not available for category 2 gases EPA (1994).

RGDR_ET_ = (Dose_ET_)_mouse_ / (Dose_ET_)_human_ = (VE / SA_ET_)_mouse_ / (VE / SA_ET_)_human_

The minute volumes (VE) for female mice were calculated using the equation LN (VE) = b_0_ + b_1_ [LN (BW in kg)].

Intercept b_0_ of 0.326, slope b_1_ of 1.050 for mouse, and chronic body weight of 0.0353 kg for chronic female B6C3F1 mice were taken from (EPA 1994).

VE_mouse_ | = mouse minute volume (L/minute) | = 41.3741 mL/minute for chronic female mice
(SA_ET_)_mouse_ | = mouse surface area of extrathoracic region | = 3 cm^3^
VE_human_ | = human minute volume (L/minute) | = 13,800 mL/minute
(SA_ET_)_human_ | = human surface area of extrathoracic region | = 200 cm^3^

An extrathoracic regional gas dose ratio of 0.1999 was calculated for female mice exposed in a chronic-duration study. These values were used to convert the female mouse BMCL value for nasal lesions to a human equivalent concentration (see below).

Since epithelial hyperplasia of the urinary bladder is an extrarespiratory effect, the conversion to a human equivalent concentration is calculated for a category 3 gas using the ratio of animal/human blood:gas partition coefficients. However, as no blood:gas partition coefficients for 1,3-dichloropropene were located in the published literature, the default ratio of 1 is applied. The human equivalent BMCL_10_ values are unchanged from the mouse values.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The exposure concentrations (in mg/m^3^ as reported by study authors) were adjusted for the purity of the compound (92.1%) and intermittent exposure (6 hours/24 hours x 5 days/7 days). Benchmark concentration analyses were conducted using these adjusted exposure levels.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No data are available for effects in humans following chronic-duration inhalation exposure to 1,3-dichloropropene. Fischer F344 rats and B6C3F1 mice were evaluated for chronic-duration inhalation exposure to Telone II^®^b (92.1% 1,3-dichloropropene stabilized with 2% epoxidized soybean oil) for 1 or 2 years (Lomax et al. 1989).

The available data from chronic-duration studies indicate that lesions of the nasal epithelium and urinary bladder in mice are the most sensitive effects associated with chronic-duration inhalation exposure to 1,3-dichloropropene. After 1 year, incidences of hypertrophy/hyperplasia of the nasal respiratory epithelium were increased in male mice exposed at ≥20 ppm and in female mice at 60 ppm. In addition, the incidences of hyperplasia and inflammation of the urinary bladder were increased in female mice exposed to 60 ppm for 1 year. After 2 years of exposure, increased incidences of hypertrophy/hyperplasia of the nasal respiratory epithelium occurred in female mice at ≥20 ppm and males exposed at 60 ppm, and increased degeneration of the nasal olfactory epithelium occurred in male and female mice exposed at 60 ppm. In rats, nasal lesions were only detected at 60 ppm after 2 years of exposure and at lower incidences than in exposed mice: decreased thickness of the olfactory epithelium in males and females, erosion of the olfactory epithelium in males, and submucosal fibrosis in males. The incidences of epithelial hyperplasia of the urinary bladder were increased in female mice exposed for 2 years at ≥20 ppm and male mice exposed at 60 ppm; the incidence of inflammation of the bladder epithelium was increased in female mice exposed for 2 years at ≥20 ppm, but not in males. No histopathology of the urinary bladder was observed in rats.

Based on these findings, hypertrophy/hyperplasia of the nasal respiratory epithelium and hyperplasia of the urinary bladder epithelium in mice exposed for 2 years were selected as co-critical effects for development of the chronic-duration inhalation MRL for 1,3-dichloropropene. The mouse study by Lomax et al. (1989) is accepted as the principal study because the test material in this adequately designed and reported study had a purity of 92.1% and did not contain epichlorohydrin or chloropicrin as a possibly confounding toxic additive.

Potential points of departure for deriving the chronic-duration inhalation MRL using benchmark concentration analysis are shown in Table A-10. Before the analysis, exposure concentrations in ppm were converted to mg/m^3^, and adjusted for 92.1% purity and discontinuous exposure. Additional details of the benchmark concentration analysis are described below. None of the models in the EPA BMD software provided an adequate fit to the data for hypertrophy/hyperplasia of the nasal respiratory epithelium in male mice, so no BMCL could be calculated. For increased incidence of hypertrophy/hyperplasia of nasal respiratory epithelium in female mice or hypertrophy of urinary bladder epithelium in male and female mice, the potential points of departure were the 95% lower confidence limits on estimated concentrations (BMCL_10_s) associated with 10% extra risk compared to control values. This benchmark response (BMR) level is the default recommended by EPA (2000a).

Table A-10 Potential Points of Departure for Determining the Chronic-duration Inhalation MRL for 1,3-Dichloropropene

End point | BMC_10_^a^ (mg/m^3^)^b^ | BMCL_10_^a^ (mg/m^3^)^b^
Hypertrophy/hyperplasia of nasal respiratory epithelium (slight) in B6C3F1 mice exposed to Telone II^®^b vapor for 2 years | M^c^; F 7.0833 | M^c^; F 4.5673
BMR = 10% extra risk
Hyperplasia of urinary bladder (slight-moderate) in B6C3F1 mice exposed to Telone II^®^b vapor for 2 years | M 9.9024; F 6.9087 | M 8.0838; F 5.9079
BMR = 10% extra risk

a Adjusted for <100% purity and discontinuous exposure

b To convert to ppm, multiply by 0.22.

c No models provided adequate fits to the data.

BMC = benchmark concentration; BMCL = 95% lower confidence limit for the benchmark concentration; BMR = benchmark response level

Source: Lomax et al. 1989

Mouse BMCL values were converted to human equivalent concentrations using EPA (1994) dosimetry methods. The BMCL_10_ of 4.5673 mg/m^3^ for hypertrophy/hyperplasia of nasal respiratory epithelium in female mice was multiplied by the extrathoracic regional dose ratio (mouse/human) of 0.1999 (calculated above), resulting in a human equivalent concentration of 0.9130 mg/m^3^ (0.2009 ppm). The default ratio of 1 was applied for calculating the human equivalent concentrations for the extrarespiratory effects and urinary bladder lesions, resulting in values unchanged from those of male and female mice: respectively, 8.0838 and 5.9079 mg/m^3^ (1.7784 and 1.2997 ppm).

The [BMCL_10_]_HEC_ value of 0.2009 ppm for hypertrophy/hyperplasia of nasal respiratory epithelium in female mice was selected as the more sensitive point of departure for the chronic-duration inhalation MRL for 1,3-dichloropropene.

The chronic-duration inhalation MRL for 1,3-dichloropropene is based on the Lomax et al. (1989) study which used technical grade dichloropropene containing 92.1% 1,3-dichloropropene, 0.7% 1,2-dichloropropene, 2% epoxidized soybean oil as a stabilizer, and a calculated 5.2% mixture of hexanes and hexadienes. It is unlikely that hexane significantly contributed to the toxicity of 1,3-dichloropropene. Although hexane and 1,3-dichloropropene both affect the olfactory epithelium, the lowest LOAEL for this effect by n-hexane is almost 2 orders of magnitude higher than for 1,3-dichloropropene. As such, the hexane and hexadiene component is not considered to be a confounder in toxicity assessments for 1,3-dichloropropene.

#### Details of Benchmark Dose Analysis for the Chronic-duration Inhalation MRL

##### Male and Female Mice

All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for hypertrophy/hyperplasia of nasal respiratory and urinary bladder epithelium in male and female B6C3F1 mice exposed to 1,3-dichloropropene via inhalation for 2 years (Table A-11). Predicted concentrations associated with 10, 5, and 1% extra risks were calculated.

Table A-11 Incidence of Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium and Urinary Bladder Epithelium in Male and Female B6C3F1 Mice Adjusted for Purity and Discontinuous Exposure

| Administered concentration (mg/m^3^)^a^ | Concentration adjusted for 92.1% purity and for discontinuous exposure (mg/m^3^)^^a^^ | Incidence
| Administered concentration (mg/m^3^)^a^ | Concentration adjusted for 92.1% purity and for discontinuous exposure (mg/m^3^)^^a^^ | Males | Females
Nasal respiratory epithelium | 0 | 0 | 5/50 | 4/50
Nasal respiratory epithelium | 22.7 | 3.7 | 1/50 | 4/50
Nasal respiratory epithelium | 90.8 | 14.9 | 4/50 | 28/50
Nasal respiratory epithelium | 272 | 44.7 | 48/50 | 49/50
Urinary bladder epithelium | 0 | 0 | 4/48 | 1/47
Urinary bladder epithelium | 22.7 | 3.7 | 7/48 | 4/46
Urinary bladder epithelium | 90.8 | 14.9 | 11/48 | 21/48
Urinary bladder epithelium | 272 | 44.7 | 37/47 | 44/45

a To convert to ppm, multiply by 0.22.

Source: Lomax et al. 1989

##### Hypertrophy/hyperplasia of nasal respiratory epithelium in male and female mice

As assessed by the chi-square goodness-of-fit test, no models in the software provided adequate fits to the data for the incidence of hypertrophy/hyperplasia of nasal respiratory epithelium in male B6C3F1 mice since all of the chi-square p-values were lower than 0.1 (data not shown). Several models in the software provided adequate fits to the data for the incidence of for hypertrophy/hyperplasia of nasal respiratory epithelium in female B6C3F1 mice (x^2^ p-value ≥0.1) (Table A-12). Comparing across models, a better fit is indicated by a lower AIC (EPA 2000b). The log-probit model was determined to be the best-fitting model for the female data, as indicated by the AIC (Table A-12). Benchmark concentrations (BMCs and BMCLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting model, are shown in Table A-15.

Table A-12 Goodness of Fit Statistics and BMC_10_s and BMCL_10_s from Models Fit to Incidence Data for Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years

Model | AIC | X^2^ p-value^a^ | BMC_10_ (mg/m^3^)^b^ | BMCL_10_ (mg/m^3^)^b^
Gamma | 140.696 | 0.4605 | 5.88054 | 3.64206
Logistic | 141.091 | 0.1720 | 5.39501 | 4.3506
Log-Logistic | 140.177 | 0.8712 | 7.6296 | 4.86553
Multistage | 142.702 | 0.1047 | 4.9972 | 2.62038
Probit | 142.872 | 0.0716 | 5.19777 | 4.23194
Log-probit ^c^ | 140.166 | 0.9004 | 7.08327 | 4.56728
Quantal-linear | 150.075 | 0.0082 | 1.90984 | 1.53078
Quantal-quadratic | 141.085 | 0.1307 | 6.30223 | 5.39173
Weibull | 141.736 | 0.2167 | 4.94384 | 3.13411

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b To convert to ppm, multiply by 0.22.

c Best-fitting model

AIC = Akaike’s Information Criteria; BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; p = p-value from the Chi-squared test

Source: Lomax et al. 1989

Figure A-3 Observed and Predicted Incidences of Hypertrophy/Hyperplasia of Nasal Respiratory Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years^*^ * BMCs and BMCLs indicated are for a 10% extra risk and are in units of mg/m^3^.

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration

Source: Lomax et al. 1989

##### The form and parameters of the log-probit model for the female mouse nasal lesion data are as follows

P [response] = Background + (1 − Background) * CumNorm (Intercept + slope * Log (Dose)) ,

where CumNorm(.) is the cumulative normal distribution function

background | = | 0.0769028
intercept | = | -4.80042
slope | = | 1.79742

##### Slight/moderate hyperplasia of urinary bladder epithelium in male and female mice

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data (x^2^ p-value ≥0.1) for the incidence of for slight/moderate hyperplasia of urinary bladder epithelium in male (Table A-13; Figure A-4) and female (Table A-14; Figure A-5) B6C3F1 mice. Comparing across models, a better fit is indicated by a lower AIC (EPA 2000b). The logistic model was determined to be the best fitting model for the male data (Table A-13), whereas the quantal quadratic model was determined to be the best-fitting model for the female data (Table A-14), as indicated by the AIC. Benchmark concentrations (BMCs and BMCLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting models for both sexes, are shown in Table A-15.

Table A-13 Goodness of Fit Statistics and BMC_10_s and BMCL_10_s from Models Fit to Incidence Data for Slight/Moderate Hyperplasia of Urinary Bladder Epithelium in Male B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years

Model | AIC | X^2^ p-value^a^ | BMC_10_ (mg/m^3^)^b^ | BMCL_10_ (mg/m^3^)^b^
Gamma | 174.596 | 0.3561 | 12.9064 | 5.9353
Logistic ^c^ | 172.196 | 0.7929 | 9.90241 | 8.08381
Log-Logistic | 174.593 | 0.3576 | 13.1008 | 7.37023
Multistage | 174.403 | 0.4119 | 10.9233 | 4.95677
Probit | 172.305 | 0.7515 | 9.13794 | 7.58289
Log-probit | 174.671 | 0.3380 | 13.5586 | 8.28718
Quantal-linear | 177.633 | 0.0631 | 4.15472 | 3.1987
Quantal-quadratic | 172.465 | 0.6951 | 12.1536 | 10.4772
Weibull | 174.465 | 0.3939 | 12.1787 | 5.68456

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b To convert to ppm, multiply by 0.22.

c Best-fitting model

AIC = Akaike’s Information Criteria; BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; p = p-value from the Chi-squared test

Source: Lomax et al. 1989

Figure A-4 Observed and Predicted Incidences of Slight/Moderate Hyperplasia of Urinary Bladder Epithelium in Male B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years^*^ * BMCs and BMCLs indicated are for a 10% extra risk and are in units of mg/m^3^.

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration

Source: Lomax et al. 1989

##### The form and parameters of the logistic model for the male mouse data are as follows

P [r e s p o n s e] = 1 / [1 + E X P (- i n t e r c e p t - s l o p e * d o s e)]

background | = | 0 (Specified)
intercept | = | -2.19615
slope | = | 0.0769886

Table A-14 Goodness of Fit Statistics and BMC_10_s and BMCL_10_s from Models Fit to Incidence Data for Slight/Moderate Hyperplasia of Urinary Bladder Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years

Model | AIC | X^2^ p-value^a^ | BMC_10_ (mg/m^3^)^b^ | BMCL_10_ (mg/m^3^)^b^
Gamma | 119.054 | 0.3665 | 5.94769 | 3.5405
Logistic | 118.133 | 0.3632 | 6.93667 | 5.55287
Log-Logistic | 120.1 | 0.1816 | 8.84738 | 5.10377
Multistage | 118.241 | 0.9777 | 4.99209 | 2.90579
Probit | 118.606 | 0.2979 | 6.62106 | 5.3209
Log-probit | 120.27 | 0.1657 | 8.76593 | 4.86738
Quantal-linear | 126.03 | 0.0206 | 2.16273 | 1.72952
Quantal-quadratic ^c^ | 117.42 | 0.5326 | 6.90872 | 5.90793
Weibull | 118.378 | 0.7085 | 5.4465 | 3.42639

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b To convert to ppm, multiply by 0.22.

c Best-fitting model

AIC = Akaike’s Information Criteria; BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; p = p-value from the Chi-squared test

Source: Lomax et al. 1989

Figure A-5 Observed and Predicted Incidences of Slight/Moderate Hyperplasia of Urinary Bladder Epithelium in Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years^*^ * BMCs and BMCLs indicated are for a 10% extra risk and are in units of mg/m^3^.

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration

Source: Lomax et al. 1989

##### The form and parameters of the quantal-quadratic model for the female mouse data are as follows

P [response] = background + (1 − background) * [1 − EXP (− slope * dose ^ 2)]

background | = | 0.03125
slope | = | 0.00169733
power | = | 2 (Specified)

Table A-15 Best-fitting Model Predictions for 1, 5, and 10% Extra Risk for Hypertrophy/Hyperplasia of Nasal Respiratory in Female and Urinary Bladder Epithelium in Male and Female B6C3F1 Mice Exposed to 1,3-Dichloropropene via Inhalation for 2 Years

Best fitting model | BMR (percent extra risk) | BMC (mg/m^3^)^a^ | BMCL (mg/m^3^)^a^
Male mice^b^
Urinary bladder epithelium: quantal quadratic | 1 | 1.30075 | 0.988608
Urinary bladder epithelium: quantal quadratic | 5 | 5.65321 | 4.47585
Urinary bladder epithelium: quantal quadratic | 10 | 9.90241 | 8.08381
Female mice
Nasal respiratory epithelium: Log-Probit | 1 | 3.96085 | 2.0326
Nasal respiratory epithelium: Log-Probit | 5 | 5.78698 | 3.45244
Nasal respiratory epithelium: Log-Probit | 10^c^ | 7.08327 | 4.56728
Urinary bladder epithelium: quantal quadratic | 1 | 2.13378 | 1.82468
Urinary bladder epithelium: quantal quadratic | 5 | 4.82046 | 4.12218
Urinary bladder epithelium: quantal quadratic | 10 | 6.90872 | 5.90793

BMC = benchmark concentration; BMCL = lower confidence limit (95%) on the benchmark concentration; BMR = benchmark response

a To convert to ppm, multiply by 0.22.

b No models provided adequate fits for the incidence data for nasal lesions in male mice.

c Best-fitting model

Source: Lomax et al. 1989

[underlined: Agency Contacts (Chemical Managers)]: Annette Ashizawa, Sharon Wilbur, and Heraline Hicks

## 1,3-Dichloropropene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,3-Dichloropropene
CAS Numbers: | 542-75-6
Date: | June 2008
Profile Status: | Final Draft Post-public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 10
Species: | Rat

[underlined: Minimal Risk Level]: 0.04 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Haut KT, Stebbins KE, Johnson KA, . 1996. Subchronic toxicity of ingested 1,3-dichloropropene in rats and mice. Fundam Appl Toxicol 32:224–232 8921325 .

[underlined: Experimental design]: Haut et al. (1996) exposed groups of male and female Fischer 344 rats (10/sex/group) to 1,3-dichloropropene at doses of 0, 5, 15, 50, or 100 mg/kg/day for 13 weeks. The test material, Telone II^®^b, was 95.8% pure 1,3-dichloropropene (50.7% cis; 45.1% trans) stabilized with epoxidized soybean oil, and was microencapsulated in a starch/sucrose (80:20) microsphere matrix before addition to the diets; separate tests showed that the microencapsulated compound was stable in feed for at least three weeks, but test diets were mixed fresh weekly. Control diets received empty microspheres in an amount equivalent to the high-dose treated group. Animals were examined daily for clinical signs of toxicity and received a weekly clinical examination. Body weights and feed intake were recorded prior to testing and weekly during the study. For rats, urinalysis was conducted during the week before the scheduled necropsy and at necropsy, blood samples were collected for hematology and clinical chemistry evaluations. At necropsy, absolute and relative organ weights were recorded for brain, liver, kidneys, heart, and adrenals. Samples of 65 tissues from all rats were preserved and those of the control and high-dose groups were examined for histopathology; gross lesions and tissues from five organs (lung, liver, kidney, stomach, female mesenteric tissues) from low- and mid-dose animals were scheduled for histopathological examination.

[underlined: Effects noted in study and corresponding doses]: Treatment with 1,3-dichloropropene had no adverse effect on survival in rats. Body weights were significantly reduced by 16% in male rats treated at 50 mg/kg/day and by 11% in female rats treated at 100 mg/kg/day; statistically significant reductions in body weights at lower doses were not biologically significant. The study authors indicated that significantly reduced feed intake at the high doses likely contributed to the reduced body weights, as well as the slightly reduced absolute organ weights and increased relative organ weights. The authors attributed minor changes in clinical chemistry parameters in rats (e.g., reduction in triglycerides) to the poorer nutritional status of high-dose rats.

A NOAEL of 5 mg/kg/day and a LOAEL of 15 mg/kg/day were identified for minimal basal cell hyperplasia of the nonglandular stomach in male rats treated at 15 mg/kg/day and female rats at 50 mg/kg/day (Table A-16). Female rats at 100 mg/kg/day also exhibited hyperkeratosis of the nonglandular stomach. These lesions represent portal-of-entry effects from ingested 1,3-dichloropropene.

Table A-16 Incidence of Histopathological Lesions of Basal Cells in the Nonglandular Stomach in F344 Rats Exposed to 1,3-Dichloropropene (Telone II^®^b) in the Diet for 13 Weeks

| Dose (doses in mg/kg/day; group size = 10)
| 0 | 5 | 15 | 50 | 100
Hyperplasia
Males | 0 | 0 | 4^a^ | 10^a^ | 10^a^
Females | 0 | 0 | 3 | 10^a^ | 10^a^
Hyperkeratosis
Males | 0 | 0 | 1 | 3 | 3
Females | 0 | 0 | 0 | 3 | 5^a^

a Statistically different from control, Fisher Exact Test performed by Syracuse Research Corporation.

Source: Haut et al. 1996

[underlined: Dose and end point used for MRL derivation]: Minimal hyperplasia of the nonglandular stomach mucosa in male Fischer 344 rats treated at 15 mg/kg/day for 13 weeks. The calculated BMDL_10_ value of 3.5722 mg/kg/day (see Table A-17) was used as the point of departure for the MRL

[ ] NOAEL [ ] LOAEL [X] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]: 100 applied to the BMDL_10_ of 3.5722 mg/kg/day for increased incidence of forestomach basal cell hyperplasia in male rats

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

3.5722 mg / kg / day / 100 = 0.0357 , rounded to 0.04 mg / kg / day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No. Study authors reported doses as calculated from feed intake.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable. Intake was ad libitum.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No data are available for effects in humans following intermediate-duration oral exposure to 1,3-dichloropropene. Intermediate-duration oral exposure studies with rats, mice, and dogs exposed to different commercial formulations of 1,3-dichloropropene isomers have been conducted by oral gavage or dietary exposure.

The available data from the oral exposure animal studies indicate that lesions in the nonglandular stomach mucosa in rats and microcytic anemia in dogs are the most sensitive effects associated with intermediate-duration oral exposure to 1,3-dichloropropene (see Chapter 3 for more detailed discussion of health effects associated with 1,3-dichloropropene). Increased incidences of basal cell hyperplasia of the nonglandular stomach occurred in male Fischer 344 rats exposed to doses ≥15 mg/kg/day Telone II^®^b microencapsulated in feed for 13 weeks; female rats displayed hyperkeratosis of the nonglandular stomach epithelium at doses of 100 mg/kg/day in this study (Haut et al. 1996). B6C3F1 mice exposed to Telone II^®^b via the same protocol for 13 weeks did not display any adverse effects on histologic or hematologic end points (Haut et al. 1996). Microcytic anemia (decreased hematocrit, hemoglobin concentration, and corpuscular volume) occurred in beagle dogs exposed to doses ≥15 mg/kg/day Telone II^®^b encapsulated in feed for 13 weeks (Stebbins et al. 1999). Reductions in terminal body weight were observed in rats, mice, and dogs exposed to Telone II^®^b in feed for 13 weeks, but reduced food intake associated with decreased palatability may have contributed to these effects (Haut et al. 1996; Stebbins et al. 1999). In an earlier 13-week study with Telone^®^, a commercial formulation of lesser 1,3-dichloropropene purity than Telone II^®^b, increased liver or kidney weights were observed in rats at doses as low as 10 and 30 mg/kg/day, respectively, but the lack of renal or kidney adverse noncancer effects in the intermediate- or chronic-duration studies with Telone II^®^b suggests that these organs are not consistently observed noncancer toxicity targets of 1,3-dichloropropene.

Basal cell hyperplasia in the nonglandular stomach of male rats and decreased hemoglobin concentration and corpuscular volume in male or female dogs were sensitive effects occurring at the same exposure levels. However, the intermediate-duration study in dogs by Stebbins et al. (1999) was judged to be inadequate as a critical study because no histopathology examination was conducted and the group sizes were small. Therefore, basal cell hyperplasia in the nonglandular stomach of male rats was selected as the critical effect for development of the intermediate-duration MRL for 1,3-dichloropropene. The 13-week study with male rats (Haut et al. 1996) exposed to microencapsulated Telone II^®^b was selected as the principal study, because the test material in these adequately designed and reported studies was the most purified 1,3-dichloropropene formulation tested and did not contain potentially confounding toxic materials such as epichlorohydrin or chloropicrin.

Potential points of departure for deriving the intermediate-duration MRL, derived with benchmark dose analysis, are shown in Table A-17. Details of the benchmark dose analyses are given below.

Table A-17 Potential Points of Departure for Determining the Intermediateduration Oral MRL for 1,3-Dichloropropene

End point | BMD (mg/kg/day) | BMDL (mg/kg/day)
Increased incidence of basal cell hyperplasia of nonglandular stomach mucosa in male rats exposed to Telone II^®^b in feed for 13 weeks (Haut et al. 1996) | 9.0030 | 3.5722
BMR = 10% extra risk

BMD = benchmark dose; BMDL = 95% lower confidence limit for the benchmark dose; BMR = benchmark response level; MRL = Minimal Risk Level

For increased incidence of basal hyperplasia in nonglandular stomach mucosa of rats, the potential point of departure was the BMDL associated with 10% extra risk; this BMR was the default recommended in EPA (2000a).

An intermediate-duration oral MRL of 0.04 mg/kg/day was derived by dividing the rat BMDL_10_ of 3.5722 mg/kg/day for basal cell hyperplasia by a composite uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). The MRL is based on the Haut et al. (1996) study which used Telone II^®^b containing 95.8% 1,3-dichloropropene with no other constituents reported.

#### Details of Benchmark Dose Analysis for the Intermediate-duration Oral MRL

##### Male Rats:

All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for basal cell hyperplasia of nonglandular stomach mucosa in male rats exposed to 1,3-dichloropropene in the diet for 13 weeks (Table A-18). Predicted doses associated with 10, 5, and 1% extra risks were calculated (Table A-20).

Table A-18 Incidence of Basal Cell Hyperplasia of Nonglandular Stomach Mucosa (minimal) in Fisher 344 Rats Exposed to 1,3-Dichloropropene in the Diet for 13 Weeks

| Doses in mg/kg body weight/day
| Control | 5 | 15 | 50 | 100
Males | 0/10 | 0/10 | 4/10^a^ | 10/10^a^ | 10/10^a^

a a Statistically different from control (Fisher Exact Test performed by SRC March 2006)

Source: Haut et al. 1996

##### Male Rats

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of basal cell hyperplasia of nonglandular stomach mucosa in male rats (x^2^ p-value ≥0.1) (Table A-19). Comparing across models, a better fit is indicated by a lower AIC (EPA 2000b). A 3-degree polynomial multi-stage model was determined to be the best-fitting model, as indicated by the AIC (Table A-19; Figure A-6). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting model, are shown in Table A-20.

Table A-19 Goodness of Fit Statistics and BMD_10_s and BMDL_10_s from Models Fit to Incidence Data for Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male Rats Exposed to 1,3-Dichloropropene in the Diet for 13 Weeks

Model | AIC | X^2^ p-value^a^ | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma | 15.4607 | 1.0000 | 11.5681 | 5.1935
Logistic | 17.4602 | 1.0000 | 14.0398 | 6.8305
Log-Logistic | 17.4602 | 1.0000 | 13.5206 | 6.25073
Multistage ^b^ | 15.8298 | 0.9957 | 9.00298 | 3.57217
Probit | 17.4602 | 1.0000 | 13.1012 | 6.25656
Log-probit | 17.4602 | 1.0000 | 12.213 | 5.92308
Quantal-linear | 22.7351 | 0.3922 | 2.40324 | 1.53389
Quantal-quadratic | 16.6383 | 0.9616 | 7.05272 | 5.01843
Weibull | 17.4612 | 1.0000 | 12.4316 | 4.82232

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Best-fitting model

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not applicable; p = p-value from the Chi-squared test

Source: Haut et al. 1996

Figure A-6 Observed and Predicted Incidences of Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male Rats Exposed to 1,3-Dichloropropene in the Diet for 13 Weeks^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: Haut et al. 1996

##### The form and parameters of the multi-stage model for the male rat data are as follows

P [response] = background + (1 − background) * [1 − EXP (− beta 1 * dose ^ 1 − beta 2 * dose ^ 2 − beta 3 * dose ^ 3)]

background | = | 0
Beta(1) | = | 0
Beta(2) | = | 0
Beta(3) | = | 0.000144384

Table A-20 Best-fitting Model Predictions for 1, 5, and 10% Extra Risk for Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male Rats Exposed to 1,3-Dichloropropene in the Diet for 13 Weeks

Best fitting model | BMR (% extra risk) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male: Multistage | 1 | 4.11358 | 0.416759
Male: Multistage | 5 | 7.0824 | 1.76019
Male: Multistage | 10 | 9.00298 | 3.57217

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; BMR = benchmark response

Source: Haut et al. 1996

[underlined: Agency Contacts (Chemical Managers)]: Annette Ashizawa, Sharon Wilbur, and Heraline Hicks

## 1,3-Dichloropropene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,3-Dichloropropene
CAS Numbers: | 542-75-6
Date: | June 2008
Profile Status: | Final Draft Post-public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 18
Species: | Rat

[underlined: Minimal Risk Level]: 0.03 [X ] mg/kg/day [ ] ppm

[underlined: References]: Co-principal studies:

Stebbins KE, Johnson KA, Jeffries TK, . 2000. Chronic toxicity and oncogenicity studies of ingested 1,3-dichloropropene in rats and mice. Regul Toxicol Pharmacol 32:1–13.11029263

Stebbins KE, Quast JF, Haut KT, . 1999. Subchronic and chronic toxicity of ingested 1,3-dichloropropene in dogs. Regul Toxicol Pharmacol 30:233–243.10620473

[underlined: Experimental design]: Stebbins et al. (2000) exposed groups of male and female Fischer 344 rats (50/sex/group) to 1,3-dichloropropene in the diet at doses of 0, 2.5, 12.5, or 25 mg/kg/day for 2 years; satellite groups of 10/sex/group were scheduled for interim sacrifice at 12 months. Stebbins et al. (1999) exposed beagle dogs (4/sex/group) to dose of 0, 0.5, 2.5, or 15 mg/kg/day for 1 year. In both studies, the test material, Telone II^®^b, was 95.8% pure 1,3-dichloropropene (50.7% cis; 45.1% trans) with 2% ESO as a stabilizer and was microencapsulated in a starch/sucrose (80:20) microsphere matrix before addition to the diets; separate tests showed that the microencapsulated compound was stable in feed for at least three weeks, but test diets were mixed fresh weekly. Control diets received empty microspheres in an amount equivalent to that given to the high-dose treated group. Animals were examined daily for clinical signs of toxicity and received a weekly clinical examination. Body weights and feed intake were recorded prior to testing and weekly during the first 13 weeks of the study and at monthly intervals thereafter. For rats, urinalysis samples and blood samples for hematology and clinical chemistry and were obtained from the satellite groups at 6 and 12 months and from survivors in the main group at 18 months (10 animals/sex/group) and 24 months (20 animals/sex/group). For dogs, blood samples were collected prior to testing and after 3, 6, and 9 months of dosing and during the week prior to termination; urine samples were taken from dogs at necropsy. At necropsy, absolute and relative organ weights were recorded for brain, liver, kidneys, testes, ovaries, heart, and adrenals in both species and for thyroids plus parathyroids in dogs. Complete sets tissues from all animals were preserved and, in rats, those of the control and high-dose groups and animals dying prematurely were examined for histopathology; gross lesions and tissues from selected organs (lung, liver, uterus, kidney, stomach, and testes) from low- and mid-dose animals were scheduled for histopathological examination. All dogs were examined for histopathology in the full range of tissues.

[underlined: Effects noted in study and corresponding doses]: Both studies: Dietary exposure to Telone II^®^b had no effect on survival in rats exposed for 2 years or dogs exposed for 1 year.

#### Rats

Body weights of high-dose male and female rats were 15–16% lower than controls, but feed consumption was also reduced by 12–13%. Exposure had no significant effect on hematology, clinical chemistry, or urinalysis parameters. Reduced triglyceride counts in high-dose males and females were attributed by the authors to the decreased body weights, rather than a toxicological response.

In rats, the most sensitive effect of exposure after 2 years was basal cell hyperplasia of the nonglandular stomach mucosa observed in male and female rats exposed at 12.5 or 25 mg/kg/day (Table A-21). The incidence of this lesion was also significantly elevated in the satellite group after 1 year of exposure in males at 12.5 mg/kg/day and in females at 25 mg/kg/day. The incidence of hepatic foci of any type was not increased with treatment, but treated rats showed increases of eosinophilic foci compared to basophilic foci. The incidence of benign hepatocellular adenomas was significantly increased in male rats at 25 mg/kg/day (incidence 2/50, 1/50, 6/50, 9/50), whereas females showed a positive trend for these tumors (incidence 0/50, 0/50, 0/50, 4/50). One male rat treated at 25 mg/kg/day had a hepatic carcinoma.

Table A-21 Incidence of Histopathological Lesions of Basal Cells in the Nonglandular Stomach in F344 Rats Exposed to 1,3-Dichloropropene (Telone II^®^b) in the Diet for 2 Years Dose (doses in mg/kg/day; group size = 50)

| Dose (doses in mg/kg/day; group size = 50)
| 0 | 2.5 | 12.5 | 25
Hyperplasia
Males | 3 | 3 | 20^a^ | 30^a^
Females | 0 | 1 | 20^a^ | 37^a^

a Statistically different from controls

Source: Stebbins et al. 2000

#### Dogs

Terminal body weights were significantly lower than controls by 11% in male dogs and 15% in female dogs exposed at 15 mg/kg/day. Exposure had no effect on feed consumption or urinalysis results. The study authors indicated that changes in clinical chemistry parameters were not associated with histopathology in any organ. In dogs, the most sensitive effects were reductions in hemoglobin, hematocrit, and mean corpuscular volume, all characteristic of microcytic anemia observed in dogs at a LOAEL of 15 mg/kg/day (Table A-22); the NOAEL was 2.5 mg/kg/day in dogs.

Table A-22 Hematological Effects in Beagle Dogs Exposed to 1,3-Dichloropropene (Telone II^®^b) in the Diet for 1 Year Dose (doses in mg/kg/day; group size = 4/sex/dose)

| Dose (doses in mg/kg/day; group size = 50)
| 0 | 0.5 | 2.5 | 15
Hemoglobin (g/dL)
Males | 17.4±1.6 | 17.5±1.0 | 13.7±1.3 | 12.3±3.1^a^
Females | 17.3±2.1 | 17.1±1.2 | 18.0±0.6 | 12.6±1.2^a^
Hematocrit (%)
Males | 57.0±4.1 | 56.6±3.0 | 55.7±1.4 | 40.5±10.4^a^
Females | 57.3±5.7 | 56.6±3.4 | 60.4±2.8 | 40.9±3.5^a^
Mean corpuscular volume (fL)
Males | 73±1 | 72±2 | 69±4 | 44±4^a^
Females | 75±3 | 73±2 | 72 ±3 | 43±5^a^

a Statistically different from control

Source: Stebbins et al. 1999

[underlined: Dose and end point used for MRL derivation]: Basal cell hyperplasia of the nonglandular stomach mucosa observed in female rats exposed at a LOAEL of 12.5 mg/kg/day for 2 years. BMDL values were calculated for these and other effects (see Table A-23). If the BMDL_10_ value of 3.5124 mg/kg/day for female rats was used as the point of departure, the derived MRL would be 0.04 mg/kg/day. This is in agreement with the EPA (2000a) chronic oral RfD of 0.03 mg/kg/day based on a BMDL_10_ of 3.4 mg/kg/day for the same data. Therefore, EPA’s BMDL_10_ of 3.4 mg/kg/day was selected as the point of departure for the chronic-duration oral MRL.

[ ] NOAEL [ ] LOAEL [X] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]: 100 applied to EPA’s BMDL_10_ of 3.4 mg/kg/day for increased incidence of forestomach basal cell hyperplasia in female rats.

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

3.4 mg / kg / day / 100 = 0.034 , rounded to 0.03 mg / kg / day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No. Study authors reported doses based on feed intake data.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable. Intake was ad libitum.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No data are available for effects in humans following chronic-duration oral exposure to 1,3-dichloropropene. Chronic-duration oral exposure studies with rats, mice, and dogs exposed to different commercial formulations of 1,3-di-chloropropene isomers have been conducted by oral gavage or dietary exposure.

As with the animal data for intermediate-duration exposure, the available data indicate that lesions in the nonglandular stomach mucosa in rats and microcytic anemia in dogs are the most sensitive effects associated with chronic-duration oral exposure to 1,3-dichloropropene (see Chapter 3 for a more detailed discussion of health effects associated with 1,3-dichloropropene). Basal cell hyperplasia of the nonglandular stomach mucosa was observed in male and female Fischer 344 rats exposed to doses as low as 12.5 mg/kg/day Telone II^®^b (but not 2.5 mg/kg/day) encapsulated in feed for 1 or 2 years (Stebbins et al. 2000), and in male and female F344 rats and female B6C3F1 mice exposed to gavage doses of 25 mg/kg/day Telone II^®^a (89% dichloropropene isomers plus 1% epichlorohydrin) 3 times/week for up to 2 years (NTP 1985). Increased incidences of this lesion did not occur in male or female B6C3F1 mice exposed to 2.5, 25, or 50 mg/kg/day Telone II^®^b encapsulated in feed for 1 or 2 years (Stebbins et al. 2000) or in male or female beagle dogs exposed to 0.5, 2.5, or 15 mg/kg/day Telone II^®^b encapsulated in feed for 1 year (Stebbins et al. 1999). However, male and female beagle dogs exposed to 15 mg/kg/day, but not 2.5 mg/kg/day, Telone II^®^b encapsulated in feed for 1 year showed decreased values for mean hematocrit, hemoglobin concentration, and corpuscular volume, compared with control values, which are indicative of microcytic anemia. Exposure-related reductions in terminal body weight were observed in rats, mice, and dogs exposed to Telone II^®^b in feed for 1 or 2 years, but reduced food intake associated with decreased palatability may have contributed to these effects (Stebbins et al. 1999, 2000).

Adverse noncancer effects on the liver or kidney are not as clearly associated with chronic-duration oral exposure to 1,3-dichloropropene as forestomach basal cell hyperplasia in rats or microcytic anemia in dogs. Exposure-related kidney effects include increased incidence of hydronephrosis in female, but not male, B6C3F1 mice exposed to gavage doses of 100 mg/kg/day Telone II^®^a, but not 50 mg/kg/day, for up to 2 years (NTP 1985) and increased incidence of nephropathy in female, but not male, Fischer 344 rats exposed to 25 or 50 mg/kg/day Telone II^®^a for up to 2 years (NTP 1985). However, no exposure-related kidney effects were observed in Fischer 344 rats, B6C3F1 mice, or beagle dogs exposed to Telone II^®^b encapsulated in feed for 1 or 2 years at doses as high as 25 mg/kg/day for rats, 50 mg/kg/day for mice, and 15 mg/kg/day for dogs (Stebbins et al. 1999; 2000). Observed noncancer effects in the liver include decreased size of hepatocytes in male, but not female, B6C3F1 mice exposed to 50 mg/kg/day, but not 25 mg/kg/day, Telone II^®^b encapsulated in feed for 1 year, but not in mice exposed for 2 years (Stebbins et al. 2000) and increased incidence of slight or very slight eosinophilic foci of altered liver cells in male and female Fischer 344 rats exposed to 2.5, 12.5, or 25 mg/kg/day Telone II^®^b encapsulated in feed for 2 years. The toxicological significance of these apparent liver effects is equivocal given the inconsistency of the findings in the mouse study and the common spontaneous occurrence of liver foci (eosinophilic or basophilic) in aged Fischer 344 rats.

Based on the findings from the chronic-duration oral exposure animal studies, basal cell hyperplasia in the nonglandular stomach of male rats and decreased hemoglobin concentration and corpuscular volume in male or female dogs were selected as co-critical effects for development of the chronic-duration MRL for 1,3-dichloropropene. The 2-year rat study (Stebbins et al. 2000) and 1-year dog study (Stebbins et al. 1999) involving exposure to microencapsulated Telone II^®^b were selected as the principal studies, because the test material in these adequately designed and reported studies was the most purified 1,3-di-chloropropene formulation tested (95.8% pure 1,3-dichloropropene—50.7% cis; 45.1% trans—with 2% epoxidized soybean oil as a stabilizer) and did not contain potentially confounding toxic materials such as epichlorohydrin or chloropicrin.

Potential points of departure for deriving the chronic-duration MRL, derived with benchmark dose analysis, are shown in Table A-23. Additional details of the benchmark dose analysis are described below.

For decreased hemoglobin concentration, which was as an index of 1,3-dichloropropene-induced microcytic anemia in dogs, potential points of departure were 95% lower confidence limits on estimated doses (i.e., BMDLs) associated with a value lower than 10th percentile values for the distribution of hemoglobin concentrations in a sample of normal beagle dogs (Table A-23).

Table A-23 Potential Points of Departure for Determining the Chronic-duration Oral MRL for 1,3-Dichloropropene

End point | BMD (mg/kg/day) | BMDL (mg/kg/day)
Decreased hemoglobin concentration in beagle dogs exposed to Telone II^®^b in feed for 1 year (Stebbins et al. 1999). | M 8.3455; F 10.978 | M 6.0453; F 8.8294
BMR = 10^th^ percentile hemoglobin concentrations in normal beagle dogs, age >1year: 14.6 mg/dL males (n=169) and 14.1 mg/dL females (n=185) (Wolford et al. 1986).
Increased incidence of basal cell hyperplasia of nonglandular stomach mucosa in Fischer 344 rats exposed to Telone II^®^b in feed for 2 years (Stebbins et al. 2000) | M 5.3432; F 5.4209 | M 4.2568; F 3.5124
BMR = 10 % extra risk

BMD = benchmark dose; BMDL = 95% lower confidence limit for the benchmark dose; BMR = benchmark response level; F = female; M = male

For increased incidence of basal hyperplasia in nonglandular stomach mucosa of rats, the potential point of departure was the BMDL associated with 10% extra risk. This benchmark response (BMR) level is the default recommended by EPA (2000a).

The lowest BMDL, the BMDL_10_ of 3.5124 mg/kg/day for increased incidence of nonglandular stomach basal cell hyperplasia in female rats, was selected as the point of departure for deriving the chronic-duration oral MRL since it should be protective against all effects.

A chronic-duration oral MRL of 0.04 mg/kg/day was derived by dividing the BMDL_10_ of 3.5124 mg/kg/day for basal cell hyperplasia of the forestomach in female rats by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). The MRL is based on the Stebbins et al. (1999, 2000) studies which used approximately 96% 1,3-dichloropropene with 2% epoxidized soybean oil as a stabilizer; no other constituents were reported.

#### Details of Benchmark Dose Analysis for the Chronic-duration Oral MRL

##### Male and Female Rats

All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for basal cell hyperplasia of nonglandular stomach mucosa in male rats, female rats, and combined male and female rats exposed to 1,3-dichloropropene in the diet for 2 years (Table A-24). Predicted doses associated with 10, 5, and 1 extra risks were calculated.

Table A-24 Incidence of Basal Cell Hyperplasia of Nonglandular Stomach Mucosa (Slight or Very Slight) in Fisher 344 Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years

| Control | 2.5 mg/kg/day | 12.5 mg/kg/day | 25 mg/kg/day
Males | 3/50 | 3/50 | 20/50 | 30/50
Females | 0/50 | 1/50 | 20/50 | 37/50
Both sexes | 3/100 | 4/100 | 40/100 | 67/100

##### Male Rats

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of basal cell hyperplasia of nonglandular stomach mucosa in male rats (x^2^ p-value ≥0.1) (Table A-25). Comparing across models, a better fit is indicated by a lower AIC (EPA 2000b). The log-probit model was determined to be the best-fitting model, as indicated by the AIC (Table A-25; Figure A-9). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting model, are shown in Table A-27.

Table A-25 Goodness of Fit Statistics and BMD_10_s and BMDL_10_s from Models Fit to Incidence Data for Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years

Model | AIC | X^2^ p-value^a^ | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma | 187.302 | 0.2589 | 4.89969 | 2.57775
Logistic | 189.052 | 0.0784 | 7.13438 | 5.92049
Log-Logistic | 186.872 | 0.3554 | 4.96556 | 2.47384
Multistage | 188.102 | 0.1603 | 4.06715 | 2.46921
Probit | 188.191 | 0.1202 | 6.62804 | 5.54609
Log-probit ^b^ | 184.503 | 0.7769 | 5.34316 | 4.25684
Quantal-linear | 186.563 | 0.3216 | 3.09733 | 2.41788
Quantal-quadratic | 188.62 | 0.0871 | 7.96066 | 6.94702
Weibull | 187.529 | 0.2243 | 4.63368 | 2.54375

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Best-fitting model

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not applicable; p = p-value from the Chi-squared test

Source: Stebbins et al. 2000

Figure A-7 Observed and Predicted Incidences of Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: Stebbins et al. 2000

##### The form and parameters of the log-probit model for the male rat data are as follows

P [response] = Background + (1 − Background) * CumNorm (Intercept + slope * Log (Dose)) ,

where CumNorm(.) is the cumulative normal distribution function

background | = | 0.0531859
intercept | = | -2.95737
slope | = | 1

##### Female Rats

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of basal cell hyperplasia of nonglandular stomach mucosa in female rats (x^2^ p-value ≥0.1) (Table A-26). Comparing across models, a better fit is indicated by a lower AIC (EPA 2000b). The log-logistic model was determined to be the best-fitting model, as indicated by the AIC (Table A-26; Figure A-8). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 10, 5, and 1%, calculated from the best fitting model, are shown in Table A-27.

Table A-26 Goodness of Fit Statistics and BMD_10_s and BMDL_10_s from Models Fit to Incidence Data for Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Female Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years

Model | AIC | X^2^ p-value^a^ | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma | 138.598 | 0.9121 | 5.25023 | 3.31605
Logistic | 148.131 | 0.0176 | 7.67354 | 6.23867
Log-Logistic ^b^ | 138.416 | 0.9973 | 5.4209 | 3.51236
Multistage | 139.663 | 0.5468 | 5.29306 | 2.91991
Probit | 145.812 | 0.0404 | 7.31771 | 5.93502
Log-probit | 138.52 | 0.9461 | 5.07542 | 3.57721
Quantal-linear | 143.267 | 0.1648 | 2.39166 | 1.92514
Quantal-quadratic | 138.493 | 0.5372 | 6.49982 | 5.81197
Weibull | 139.013 | 0.7530 | 5.08921 | 3.1648

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Best-fitting model

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not applicable; p = p-value from the Chi-squared test

Source: Stebbins et al. 2000

Figure A-8 Observed and Predicted Incidences of Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Female Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: Stebbins et al. 2000

##### The form and parameters of the log-logistic model for the female rat data are as follows

P [response] = Background + (1 − Background) / [1 + EXP (-intercept − slope * Log (Dose))]

background | = | 0
intercept | = | −5.8536
slope | = | 2.14828

Table A-27 Best-fitting Model Predictions for 1, 5, and 10% Extra Risk for Basal Cell Hyperplasia of Nonglandular Stomach Mucosa in Male and Female Rats Exposed to 1,3-Dichloropropene in the Diet for 2 Years

Best fitting model | BMR (% extra risk) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male: Log-Probit | 1 | 2.10426 | 1.25833
Male: Log-Probit | 5 | 3.7369 | 2.48751
Male: Log-Probit | 10 | 5.34316 | 4.25684
Female: Log-logistic | 1 | 1.13014 | 0.258277
Female: Log-logistic | 5 | 3.13078 | 1.23116
Female: Log-logistic | 10 | 5.4209 | 3.51236

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; BMR = benchmark response

Source: Stebbins et al. 2000

##### Male and Female Dogs

The linear model in the EPA Benchmark Dose Software (BMDS version 1.3.2) was fit to the data (Table A-28) for decreased hemoglobin concentration in beagle dogs exposed to 1,3-dichloropropene in the diet for 1 year. The linear model was selected as it is the simplest model available in the BMD software which adequately fits the hemoglobin concentration data. Hemoglobin concentration was selected as the most clearly adverse variable associate with 1,3-dichloropropene-induced microcytic anemia. BMDs and BMDLs associated with a value lower than the 10^th^ percentile value for hemoglobin in normal beagle dogs were calculated (Table A-29, Figures A-9 and A-10). The 10^th^ percentile hemoglobin concentrations in normal beagle dogs, age >1 year for the 1-year exposure were 14.6 mg/dL for males and 14.1 mg/dL for females (Wolford et al. 1986).

Table A-28 Hemoglobin Concentrations in Male and Female Beagle Dogs Exposed for 1 Year

Dose mg/kg/day | Male mean hemoglobin concentration ± standard deviation (g/dL) | Female Mean hemoglobin concentration ± standard deviation (g/dL)
0 | 17.4±1.6 | 17.3±2.1
0.5 | 17.5±1.0 | 17.1±1.2
2.5 | 13.7±1.3 | 18.0±0.6
15 | 12.3±3.1* | 12.6±1.2*

Source: Stebbins et al. 1999

Table A-29 Linear Model Predictions for the Dose Associated with the 10^th^ Percentile Value for Hemoglobin Concentration in Normal Beagle Dogs with the 95% Lower Confidence Limit

Data-set | BMD_10th%ile_ (mg/kg/day) | BMDL_10th%ile_ (mg/kg/day)
Chronic
Male^a^ | 8.3455 | 6.04528
Female | 10.978 | 8.82939

a Nonhomogeneous variance model

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Figure A-9 Linear (Nonhomogeneous Variance) Model Predicted Change in Hemoglobin Concentration in Male Beagle Dogs Exposed to 1,3-Dichloropropene in the Diet for 1 Year^*^ * BMDs and BMDLs indicated are doses associated with the 10^th^ percentile value for hemoglobin concentration in normal beagle dogs and are in units of mg/kg/day.

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: Stebbins et al. 1999

Figure A-10 Linear Model Predicted Change in Hemoglobin Concentration in Female Beagle Dogs Exposed to 1,3-Dichloropropene in the Diet for 1 Year^*^ * BMDs and BMDLs indicated are doses associated with the 10^th^ percentile value for hemoglobin concentration in normal beagle dogs and are in units of mg/kg/day

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: Stebbins et al. 1999

[underlined: Agency Contacts (Chemical Managers)]: Annette Ashizawa, Sharon Wilbur, and Heraline Hicks