# CHAPTER 8 REFERENCES

ACGIH. 2014. Propylene dichloride. In: Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Ahrens W, Merletti F, Mirabelli D. 2014. Biliary tract cancer in male printers and typesetters in the European rare cancer case-control study. Occup Environ Med 71(8):591–592. 10.1136/oemed-2014-102322.
Akiba N, Shiizaki K, Matsushima Y, . 2017. Influence of GSH S-transferase on the mutagenicity induced by dichloromethane and 1,2-dichloropropane. Mutagenesis 32(4):455–462. 10.1093/mutage/gex014.28521016
Ali SM, Bowes GW, Cohen DB. 1986. Occurrence and fate of 1,2-dichloropropane in California USA ground water and soil samples. In: Abstracts of Papers - 191st National Meeting, New York, NY, April 13-18, 1986. Vol. 26. Washington, DC: American Chemical Society, 41.
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290.6376602
Anonymous. 1983. Biodegradability tests with chlorinated compounds with cover letter. Anonymous. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0215099. 878220823.
Ashley DL, Bonin MA, Cardinali FL, . 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Ashley DL, Bonin MA, Cardinali FL, . 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7 Part 2):1401–1404.8013127
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 86(1):69–201.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2005. Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/tp67.pdf. October 8, 2020.
ATSDR. 2020. Technical document for the shower and household water-use exposure (SHOWER) model v2.0. Agency for Toxic Substances and Disease Registry.
Aylward LL, Kirman CR, Blount BC, . 2010. Chemical-specific screening criteria for interpretation of biomonitoring data for volatile organic compounds (VOCs) - application of steady-state PBPK model solutions. Regul Toxicol Pharmacol 58(1):33–44. 10.1016/j.yrtph.2010.05.011.20685286
Barkley J, Bunch J, Bursey JT, . 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment-A multimedia environmental study. Biomed Mass Spectrom 7(4):139–147.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bartels MJ, Timchalk C. 1990. 1,2-Dichloropropane: investigation of the mechanism of mercapturic acid formation in the rat. Xenobiotica 20(10):1035–1042.2082593
Baruffini A, Cirla AM, Pisati G, . 1989. Allergic contact dermatitis from 1,2-dichloropropane. Contact Dermatitis 20(5):379–380.2527719
Bennett H. 1981. 1,2-Dichloropropane. In: Encyclopedia of chemical trademarks and synonyms. Vol. 1. New York, NY: Chemical Publishing Co., Inc., 210.
Berdasco NM, Johnson KA, Hanley TR. 1988. Propylene dichloride: Oral teratology probe study in New Zealand white rabbits with cover letter dated 100188. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516583. 86-890000004.
Botta D, Pirri LC, Mantica E. 1984. Ground water pollution by organic solvents and their microbial degradation products. In: Analysis of organic micropollutants in water. New York, NY: Springer, 261–275.
Bruckner JV, MacKenzie WF, Ramanathan R, . 1989. Oral toxicity of 1,2-dichloropropane: acute, short-term, and long-term studies in rats. Fundam Appl Toxicol 12(4):713–730.2744274
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past agency for toxic substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Cadena F, Eiceman GA, Vandiver VJ. 1984. Removal of volatile organic pollutants from rapid streams. J Water Pollut Control Fed 56:460–463.
Cappellini MD, Fiorelli G. 2008. Glucose-6-phosphate dehydrogenase deficiency. Lancet 371(9606):64–74. 10.1016/S0140-6736(08)60073-2.18177777
Carpenter CP, Smyth HF, Pozzani UC. 1949. The assay of acute vapor toxicity, and the grading and interpretation of results on 96 chemical compounds. J Ind Hyg Toxicol 31(6):343–346.15407114
CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables, January 2019, Volume 1. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. October 8, 2020.
ChemIDplus. 2017. 1,2-Dichloropropane. ChemIDplus: A Toxnet database. Bethesda, MD: U.S. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/. June 26, 2017.
Chiappino G, Secchi GC. 1968. [Description of a case of acute poisoning from accidental ingestion of 1,2-dichloropropane, sold as trilene]. Med Lav 59(5):334–341. (Italian)5680815
Chiou CT, Peters LJ, Freed VH. 1979. A physical concept of soil-water equilibria for nonionic organic compounds. Science 206(4420):831–832. 10.1126/science.206.4420.831.17820762
Chiou CT, Freed VH, Peters LJ, . 1980. Evaporation of solutes from water. Environ Int 3(3):231–236. 10.1016/0160-4120(80)90123-3.
Choi DW, Moon KW, Byeon SH, . 2009. Indoor volatile organic compounds in atopy patients’ houses in South Korea. Indoor Built Environ 18(2):144–154. 10.1177/1420326x08101945.
Chroust K, Pavlova M, Prokop Z, . 2007. Quantitative structure-activity relationships for toxicity and genotoxicity of halogenated aliphatic compounds: wing spot test of Drosophila melanogaster. Chemosphere 67(1):152–159. 10.1016/j.chemosphere.2006.09.020.17113125
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen DB. 1986. Ground water contamination by toxic substances. In: Evaluation of pesticides in ground water. Vol. 315. Washington, DC: American Chemical Society, 499–529. 2016/11/03.
Cohen SZ, Creeger SM, Carsel RF, . 1984. Potential pesticide contamination of groundwater from agricultural uses. In: Treatment and disposal of pesticide wastes. Vol. 259. Washington, DC: American Chemical Society, 297–325. 2017/07/10.
Cole R, Frederick R, Healy R, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Comba ME, Kaiser KLE. 1983. Determination of volatile contaminants at the ng I-1 level in water by capillary gas chromatography with electron capture detection. Int J Environ Anal Chem 16(1):17–31.
Crebelli R, Conti G, Conti L, . 1984. Induction of somatic segregation by halogenated aliphatic hydrocarbons in Aspergillus nidulans. Mutat Res 138(1):33–38.6387478
De Bortoli M, Knöppel H, Pecchio E, . 1986. Concentrations of selected organic pollutants in indoor and outdoor air in Northern Italy. Environ Int 12(1):343–350. 10.1016/0160-4120(86)90048-6.
De Lorenzo F, Degl’Innocenti S, Ruocco A, . 1977. Mutagenicity of pesticides containing 1,3-dichloropropene. Cancer Res 37(6):1915–1917.322862
Di Nucci A, Imbriani M, Ghittori S, . 1988. 1,2-Dichloropropane-induced liver toxicity: Clinical data and preliminary studies in rats. Arch Toxicol 12:370–374.
Di Nucci A, Gregotti C, Manzo L, . 1990. 1,2-Dichloropropane hepatotoxicity in rats after inhalation exposure. J Appl Toxicol 10(6):391–394.2084176
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Dow Chemical Co. 1968. Hepatotoxic potency of propylene dichloride vapors relative to their narcotic and lethal potencies in mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206134. 878210624.
Dow Chemical Co. 1983. Letter summarizing the EPA/Dow Chemical Co. meeting regarding the manufacture of 1,2-dichloropropane. Dow Chemical Company. Submitted to U.S. EPA under TSCA Section 4. OTS0511731. 40-8367072. 42043 D4A-1.
Drew RT, Patel JM, Lin FN. 1978. Changes in serum enzymes in rats after inhalation of organic solvents singly and in combination. Toxicol Appl Pharmacol 45(3):809–819.214898
EPA. 1980. Water treatment process modifications for trihalomethane control and organic substances in the Ohio River. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600280028. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20006F4V.txt. October 8, 2020.
EPA. 1981. Engineering handbook for hazardous waste incineration. Cincinnati, OH: U.S. Environmental Protection Agency. SW889. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000KAVZ.txt. August 1, 2017.
EPA. 1982a. Purgeable halocarbons, Method 601 and Purgeable, Method 624. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600482057. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=3000204R.txt. July 10, 2017.
EPA. 1982b. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency.
EPA. 1986. Toxic substances; 1,2-dichloropropane; testing requirements. Final rule. U.S. Environmental Protection Agency. Fed Regist 51:32079–32087.
EPA. 1987a. Toxic air pollutant/source crosswalk - A screening toll for locating possible sources emitting toxic air pollutants. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA45087023a.
EPA. 1987b. Determination of Henry’s Law constants of selected priority pollutants Cincinnati, OH: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100LHQP.txt. August 1, 2017.
EPA. 1991. 1,2-Dichloropropane; CASRN 78-87-5. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0601_summary.pdf. May 3, 2017.
EPA. 1992. Dermal exposure assessment: Principles and applications. Washington, DC: U.S. Environmental Protection Agency. EPA600891011B. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001L2F.txt. November 10, 2020.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1995. 1,2-Dichloropropane. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA811F95004C. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20001S3O.txt. July 13, 2017.
EPA. 1998. Reregistration eligibility decision (RED). 1,3-Dichloropropene. Washington, DC: U.S. Environmental Protection Agency. EPA738R98016. https://www3.epa.gov/pesticides/chem_search/reg_actions/reregistration/red_PC-029001_1-Sep-98.pdf. July 7, 2017.
EPA. 1999. Compendium of methods for the determination of toxic organic compounds in ambient air, second edition. Washington, DC: U.S. Environmental Protection Agency. EPA625R96010b. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005GTQ.txt. October 8, 2020.
EPA. 2000. National air pollutant emission trends, 1900-1998. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA454R00002.
EPA. 2002. Method 8265. Volatile organic compounds in water, soil, soil gas, and air by direct sampling ion trap mass spectrometry (DSITMS). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/8265.pdf. July 13, 2017.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990–2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100GL6W.txt. October 7, 2020.
EPA. 2012. 1,2-Dichloropropane. CAS 78-87-5. Estimation Program Interface (EPI Suite) version 4.11. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/exposure/pubs/episuitedl.htm. July 27, 2017.
EPA. 2014a. 2014 national emissions inventory (NEI) data: 1,2-Dichloropropane. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2014-national-emissions-inventory-nei-data. July 18, 2017.
EPA. 2014b. Duke Energy coal ash spill in Eden, NC. History and response timeline. U.S. Environmental Protection Agency. https://www.epa.gov/dukeenergy-coalash/history-and-response-timeline. July 13, 2014.
EPA. 2014c. Eden North Carolina coal ash spill surface water results. Sampling results for Duke Energy Coal Ash spill in Eden, NC. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-06/documents/final-w-maps-2014-0211-surfacewater-team2.pdf. July 7, 2017.
EPA. 2014d. Surface water data - EPA Team 2 - February 7, 2014. Sampling Results for Duke Energy Coal Ash Spill in Eden, NC. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-08/documents/final-epa-sesd-sw-02-07-14.pdf. July 7, 2017.
EPA. 2014e. Surface water data - EPA Team 2 - February 6, 2014. Sampling Results for Duke Energy Coal Ash Spill in Eden, NC. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-08/documents/final-epa-sesd-sw-02-06-14.pdf. July 7, 2017.
EPA. 2016a. Provisional peer-reviewed toxicity values for 1,2-dichloropropane (CASRN 78-87-5). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R16002F. https://hhpprtv.ornl.gov/issue_papers/Dichloropropane12.pdf. January 25, 2017.
EPA. 2016b. Chemical data access tool (CDAT). U.S. Environmental Protection Agency. https://java.epa.gov/oppt_chemical_search/. July 31, 2017.
EPA. 2016c. Air data: Air quality data collected at outdoor monitors across the United States. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/documents/data_mart_welcome.html. November 2, 2016.
EPA. 2016d. Memorandum: Grenada manufacturing ambient air sampling event. Final Report. Athens, GA: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-04/documents/grenada_manufacturing_final_report_16-0152_metadata.pdf. July 12, 2017.
EPA. 2017a. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/2016-chemical-data-reporting-results. August 10, 2017.
EPA. 2017b. Air toxics data. Ambient monitoring archive. U.S. Environmental Protection Agency. https://www3.epa.gov/ttnamti1/toxdat.html#data. April 13, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020a. Use report for 1,2-dichloropropane (CASRN 78-87-5). U.S. Environmental Protection Agency. EPA-HQ-OPPT-2018-0428-0021. https://beta.regulations.gov/document/EPA-HQ-OPPT-2018-0428-0021. October 8, 2020.
EPA. 2020b. Air toxics data. Ambient monitoring archive. U.S. Environmental Protection Agency. https://www3.epa.gov/ttnamti1/toxdat.html#data. October 2, 2020.
Exxon. 1981a. Acute oral toxicity study in rats. Exxon Chemical Americas. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206271. 878211458.
Exxon. 1981b. Acute dermal toxicity study in rabbits with cover letter. Exxon Chemical Americas. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206271. 878211458.
Exxon. 1981c. Eye irritation study in rabbits. Exxon Chemical Americas. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206271. 878211454.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Fiaccadori E, Maggiore U, Rotelli C, . 2003. Acute renal and hepatic failure due to accidental percutaneous absorption of 1,2-dichloropropane contained in a commercial paint fixative. Nephrol Dial Transplant 18(1):219–220.12480995
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17(5):617–636.2337085
Fletcher KE, Loffler FE, Richnow HH, . 2009. Stable carbon isotope fractionation of 1,2-dichloropropane during dichloroelimination by Dehalococcoides populations. Environ Sci Technol 43(18):6915–6919.19806720
Frank JE. 2005. Diagnosis and management of G6PD deficiency. Am Fam Physician 72(7):1277–1282.16225031
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: evaluations of 108 chemicals. Environ Mol Mutagen 10(Suppl 10):1–175.3319609
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008x(89)90137-3.2929023
Ghittori S, Imbriani M, Pezzagno G, . 1987. The urinary concentration of solvents as a biological indicator of exposure: proposal for the biological equivalent exposure limit for nine solvents. Am Ind Hyg Assoc J 48(9):786–790.3687738
Gi M, Fujioka M, Yamano S, . 2015a. Determination of hepatotoxicity and its underlying metabolic basis of 1,2-dichloropropane in male Syrian hamsters and B6C3F1 mice. Toxicol Sci 145(1):196–208. 10.1093/toxsci/kfv045.25711234
Gi M, Fujioka M, Yamano S, . 2015b. Modifying effects of 1,2-dichloropropane on N-nitrosobis(2-oxopropyl)amine-induced cholangiocarcinogenesis in male Syrian hamsters. J Toxicol Sci 40(5):647–656. 10.2131/jts.40.647.26354381
Gonzalez FJ, Gelboin HV. 1994. Role of human cytochromes p450 in the metabolic activation of chemical carcinogens and toxins. Drug Metab Rev 26(1–2):165–183.8082563
Gorzinski SJ, Johnson KA. 1989. Neurotoxicologic examination of Fischer 344 rats exposed to 1,2-dichloropropane (DCP) via gavage for 2 weeks. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517725. 86-890000125.
Grzywa Z, Rudzki E. 1981. Dermatitis from dichloropropane. Contact Dermatitis 7(3):151–152. 10.1111/j.1600-0536.1981.tb04589.x.6456110
Hanley TRJ, Kirk HD, Bond DM, . 1989. Propylene dichloride: Dominant lethal study in Sprague-dawley rats (Final) with cover letters. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0527736. 40-8967205.
Harcke SJ, Rizzolo D, Harcke HT. 2019. G6PD deficiency: An update. JAAPA 32(11):21–26. 10.1097/01.JAA.0000586304.65429.a7.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):1–142.
Haynes WM, Lide DR, Bruno TJ. 2014. Critical constants of organic compounds. In: CRC Handbook of Chemistry and Physics. 95th ed. Boca Raton, FL: CRC Press, 6–62.
Heppel LA, Neal PA, Highman B, . 1946a. Toxicology of 1,2-dichloropropane (propylene dichloride) studies on effects of daily inhalations. J Ind Hyg Toxicol 28:1–8.21016029
Heppel LA, Highman B, Porterfield VT. 1946b. Toxicology of 1,2-dichloropropane (propylene dichloride); influence of dietary factors on the toxicity of dichloropropane. J Pharmacol Exp Ther 87:11–17.20986674
Heppel LA, Highman B, Peake EG. 1948. Toxicology of 1,2-dichloropropane (propylene dichloride) effects of repeated exposures to a low concentration of the vapor. J Ind Hyg Toxicol 30(3):189–191.18865921
Highman B, Heppel LA. 1946. Toxicology of 1,2-dichloropropane (propylene dichloride); pathologic changes produced by a short series of daily exposures. Arch Pathol 42(5):525–534.
Hines RN. 2007. Ontogeny of human hepatic cytochromes P450. J Biochem Mol Toxicol 21(4):169–175.17936930
Horvath AL. 1982. 1,2-Dichloropropane. In: Halogenated hydrocarbons: Solubility-miscibility with water. New York, NY: Marcel Dekker, Inc., 740.
Hutson DH, Moss JA, Pickering BA. 1971. The excretion and retention of components of the soil fumigant D-D and their metabolites in the rat. Food Cosmet Toxicol 9(5):677–680.5157560
IARC. 1986. 1,2-Dichloropropane. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Lyon, France: International Agency for Research on Cancer. Vol. 41, 131–147. https://monographs.iarc.fr/ENG/Monographs/vol1-42/mono41.pdf. December 1, 2016.
IARC. 2017. 1,2-Dichloropropane. Some chemicals used as solvents and in polymer manufacture. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 110. Lyon, France: International Agency for Research on Cancer. 141–175. https://publications.iarc.fr/547. October 11, 2020.
Imberti R, Mapelli A, Colombo P, . 1990. 1,2-Dichloropropane (DCP) toxicity is correlated with DCP-induced glutathione (GSH) depletion and is modulated by factors affecting intracellular GSH. Arch Toxicol 64(6):459–465.1980407
IRIS. 2002. 1,2-Dichloropropane; CASRN 78-87-5. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0601_summary.pdf. May 3, 2017.
Jin M, Hong Y, Lee H, . 2019. 1,2-Dichloropropane (1,2-DCP)-induced angiogenesis in dermatitis. Toxicol Res 35(4):361–369. 10.5487/tr.2019.35.4.361.31636847
Johnson KA, Gorzinski SJ. 1988. Letter from Dow Chemical Company to US EPA regarding submission of final study reports for 1,2-dichloropropane with attachments. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0527733. 40-8867156.
Jones AR, Gibson J. 1980. 1,2-Dichloropropane: metabolism and fate in the rat. Xenobiotica 10(11):835–846.7467399
Kaiser KL, Comba ME, Huneault H. 1983. Volatile halocarbon contaminants in the Niagara River and in Lake Ontario. J Great Lakes Res 9(2):212–223.
Kawai T, Mitsuyoshi K, Ikeda M. 2015. Promising biological monitoring for occupational 1,2-dichloropropane exposure by urinalysis for unmetabolized solvent. J Occup Health 57(2):197–199. 10.1539/joh.14-0234-OA.25735626
Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: an approach to structure-activity correlations. Ecotoxicol Environ Saf 4(4):444–454.7472248
Kawasaki Y, Tsuboi C, Yagi K, . 2015. Photoinitiators enhanced 1,2-dichloropropane-induced cytotoxicity in human normal embryonic lung fibroblasts cells in vitro. Environ Sci Pollut Res Int 22(6):4763–4770. 10.1007/s11356-014-3939-8.25501643
Kennedy GLJ, Graepel GJ. 1991. Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett 56(3):317–326.2035177
Kincannon DF, Weinert A, Padorr R, . 1983. Predicting treatability of multiple organic priority pollutant waste water from single-pollutant treatability studies. In: Bell JM, ed. Proceedings of the 37th Industrial Waste Conference. Ann Arbor, MI: Ann Arbor Science Publishers, 641–650.
King L, Sherbin G. 1986. Point sources of toxic organics to the upper St. Clair River. Water Pollut Res J Can 21:433–446.
Kinoshita M, Kubo S, Nakanuma Y, . 2016. Pathological spectrum of bile duct lesions from chronic bile duct injury to invasive cholangiocarcinoma corresponding to bile duct imaging findings of occupational cholangiocarcinoma. J Hepatobiliary Pancreat Sci 23(2):92–101. 10.1002/jhbp.305.26580863
Kinoshita M, Sato Y, Nebiki H, . 2019. Occupational cholangiocarcinoma diagnosed 18 years after the end of exposure to 1,2-dichloropropane and dichloromethane at a printing company: a case report. Surg Case Rep 5(1):65. 10.1186/s40792-019-0624-7.31016414
Kirk DW, Hanley TR, Johnson KA. 1988. Propylene dichloride: a 13-day repeated oral gavage study in New Zealand white rabbits with attached appendix and cover letter dated 011389 Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516642. 86890000079.
Kirk HD, Hanley TRJ, Johnson KA, . 1989. Propylene dichloride: Oral teratology study in Sprague-Dawley rats with cover letter. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0527712. 40-8967191.
Kirk HD, Hanley TR, Bond DM, . 1990. Propylene dichloride: Two-generation reproduction study in Sprague-Dawley rats (final) with cover letter. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0527738. 40-9067215.
Kirk HD, Berdasco NM, Breslin WJ, . 1995. Developmental toxicity of 1,2-dichloropropane (PDC) in rats and rabbits following oral gavage. Fundam Appl Toxicol 28(1):18–26.8566479
Kirman CR, Aylward LL, Blount BC, . 2012. Evaluation of NHANES biomonitoring data for volatile organic chemicals in blood: application of chemical-specific screening criteria. J Expo Sci Environ Epidemiol 22(1):24–34. 10.1038/jes.2011.37.21989501
Kramers PG, Mout HC, Bissumbhar B, . 1991. Inhalation exposure in Drosophila mutagenesis assays: experiments with aliphatic halogenated hydrocarbons, with emphasis on the genetic activity profile of 1,2-dichloroethane. Mutat Res 252(1):17–33.1996129
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo S, Takemura S, Sakata C, . 2013. [Cholangiocarcinoma developing in printing company workers: a new type of occupational cancer]. Gan To Kagaku Ryoho 40(11):1451–1454. (Japanese)24231699
Kubo S, Nakanuma Y, Takemura S, . 2014a. Case series of 17 patients with cholangiocarcinoma among young adult workers of a printing company in Japan. J Hepatobiliary Pancreat Sci 21(7):479–488. 10.1002/jhbp.86.24420816
Kubo S, Kinoshita M, Takemura S, . 2014b. Characteristics of printing company workers newly diagnosed with occupational cholangiocarcinoma. J Hepatobiliary Pancreat Sci 21(11):809–817. 10.1002/jhbp.137.25088751
Kubo S, Matsuzaki K, Seki T, . 2015. Severe acute hepatitis in a printing company worker: a case study. J Occup Health 57(1):87–90. 10.1539/joh.14-0122-CS.25410269
Kubo S, Takemura S, Tanaka S, . 2018. Occupational cholangiocarcinoma caused by exposure to 1,2-dichloropropane and/or dichloromethane. Ann Gastroenterol Surg 2(2):99–105. 10.1002/ags3.12051.29863124
Kumagai S. 2014. Two offset printing workers with cholangiocarcinoma. J Occup Health 56(2):164–168.24553624
Kumagai S, Kurumatani N, Arimoto A, . 2013. Cholangiocarcinoma among offset colour proof-printing workers exposed to 1,2-dichloropropane and/or dichloromethane. Occup Environ Med 70(7):508–510. 10.1136/oemed-2012-101246.23493378
Kumagai S, Kurumatani N, Arimoto A, . 2014. Time course of blood parameters in printing workers with cholangiocarcinoma. J Occup Health 56(4):279–284.24826961
Kumagai S, Sobue T, Makiuchi T, . 2016. Relationship between cumulative exposure to 1,2-dichloropropane and incidence risk of cholangiocarcinoma among offset printing workers. Occup Environ Med 73(8):545–552. 10.1136/oemed-2015-103427.27371662
Kwak KM, Jeong KS, Shin DH, . 2018. Acute toxic encephalopathy induced by occupational exposure to 1,2-dichloropropane. Ind Health 56(6):561–565. 10.2486/indhealth.2018-0118.29973469
Langer E, Rassaerts H, Kleinschmidt P, . 2011. Chloropropanes, chlorobutanes, and chlorobutenes. In: Ullmann’s encyclopedia of industrial chemistry. Wiley-VCH Verlag GmbH & Co, online. 10.1002/14356007.o07_o01.
Larcan A, Lambert H, Laprevote MC, . 1977. Acute poisoning induced by dichloropropane. Acta Pharmacol Toxicol (Copenh) 41(Suppl 2):330.302583
Larranaga MD, Lewis RJ, Lewis RA. 2016. Propylene dichloride. In: Hawley’s condensed chemical dictionary. 16th ed. Hoboken, NJ: John Wiley & Sons, Inc., 1141.
Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain - II. Gas scavenging of neutral organic compounds. Atmos Environ 19(10):1609–1617.
Linnett SL, Clark DG, Blair D, . 1988. Effects of subchronic inhalation of D-D (1,3-dichloropropene/1,2-dichloropropane) on reproduction in male and female rats. Fundam Appl Toxicol 10(2):214–223. 10.1016/0272-0590(88)90305-3.3356308
Loffler FE, Champine JE, Ritalahti KM, . 1997. Complete reductive dechlorination of 1,2-dichloropropane by anaerobic bacteria. Appl Environ Microbiol 63(7):2870–2875.16535654
Lucantoni C, Grottoli S, Gaetti R. 1991. [Massive hepatocellular necrosis and hemolytic anemia in accidental inhalation of 1 2 dichloropropane description of a clinical case]. Riv Patol Clin Sper 21(2–3):105–111. (Italian)
Lucantoni C, Grottoli S, Gaetti R. 1992. 1,2-Dichloropropane is a renal and liver toxicant. Toxicol Appl Pharmacol 117(1):133.1440608
MacBean C. 2010. 1,2-Dichloropropane. In: The e-Pesticide manual. Version 5.1. 15th ed. London, United Kingdom: British Crop Protection Council, online.
Mackay D, Yeun AT. 1983. Mass transfer coefficient correlations for volatilization of organic solutes from water. Environ Sci Technol 17(4):211–217. 10.1021/es00110a006.22304636
Matsumoto T, Okura Y, Okawa Y, . 1982. Acute toxicity testing of some chlorinated lower hydrocarbons: Dichloromethane, 1,2-dichloropropane and 1,3-dichloropropane. Jpn J Toxicol Environ Health (Eisei Kagaku) 28:e31.
Matsumoto M, Umeda Y, Take M, . 2013. Subchronic toxicity and carcinogenicity studies of 1,2-dichloropropane inhalation to mice. Inhal Toxicol 25(8):435–443. 10.3109/08958378.2013.800618.23808637
McCarthy MC, Hafner HR, Montzka SA. 2006. Background concentrations of 18 air toxics for North America. J Air Waste Manag Assoc 56(1):3–11.16499141
MDEQ. 2012. Typical indoor air concentrations of volatile organic compounds in non-smoking Montana residences not impacted by vapor intrusion. Montana Department of Environmental Quality. https://deq.mt.gov/Portals/112/Land/StateSuperfund/Documents/VI_guide/CompleteIndoorVOCReport.pdf. October 7, 2020.
Meister RT. 1987. Propylene dichloride. In: Farm chemicals handbook ’87. Willoughby, OH: Meister Publishing Co., C212.
Mimaki S, Totsuka Y, Suzuki Y, . 2016. Hypermutation and unique mutational signatures of occupational cholangiocarcinoma in printing workers exposed to haloalkanes. Carcinogenesis 37(8):817–826. 10.1093/carcin/bgw066.27267998
Myhr BC, Caspary WJ. 1991. Chemical mutagenesis at the thymidine kinase locus in L5178Y mouse lymphoma cells: results for 31 coded compounds in the national toxicology program. Environ Mol Mutagen 18:51–83.1864269
Myhr BC, Bowers LR, Caspary W. 1988. Chemical testing with a CHO/HGPRT suspension culture mutation assay. Environ Mol Mutagen 11(Suppl 11):76.
Nakagawa K, Katayose Y, Ishida K, . 2015. [Occupational cholangiocarcinoma in a printer that responded to neoadjuvant chemoradiotherapy]. Nihon Shokakibyo Gakkai Zasshi 112(7):1341–1347. 10.11405/nisshoshi.112.1341. (Japanese)26155867
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35.
Nater JP, Gooskens VH. 1976. Occupational dermatosis due to a soil fumigant. Contact Dermatitis 2(4):227–229.139277
NEMI. 1998. Sampling and analytical methods of the national status and trends program mussel watch project: 1993-1996 Update. National Environmental Methods Index. NOS ORCA 130. https://www.nemi.gov/methods/method_summary/7175/. July 10, 2017.
Niehoff NM, Gammon MD, Keil AP, . 2019. Airborne mammary carcinogens and breast cancer risk in the Sister Study. Environ Int 130:104897. 10.1016/j.envint.2019.06.007.31226564
NIOSH. 1989. Propylene DiChl. 1988 OSHA PEL Project Documentation. Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/pel88/78-87.html. July 12, 2017.
NIOSH. 1994. Propylene dichloride: Method 1013. NIOSH Manual of Analytical Methods. National Institute of Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/1013.pdf. July 12, 2107.
NIOSH. 2014. Propylene dichloride. Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/78875.html. May 3, 2017.
NIOSH. 2019. 1,2-Dichloropropane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0631.html. October 11, 2020.
NITE. 2017a. 1,2-Dichloropropane. CAS 78-87-5. Bioaccumulation: Aquatic/sediment. Chemical management field. NITE Chemical Risk Information Platform (NITE-CHRIP). National Institute of Technology and Evaluation. http://www.nite.go.jp/en/chem/chrip/chrip_search/srhInput. July 28, 2017.
NITE. 2017b. 1,2-Dichloropropane. CAS 78-87-5. Biodegradation in water: Screening tests. Chemical management field. NITE Chemical Risk Information Platform (NITE-CHRIP). National Institute of Technology and Evaluation. http://www.nite.go.jp/en/chem/chrip/chrip_search/srhInput. July 28, 2017.
Nitschke KD, Johnson KA. 1983. Propylene dichloride: One day and two week inhalation toxicity in rats, mice, and rabbits. Midland, MI: Dow Chemical Company.
Nitschke KD, Johnson KA, Wackerle DL, . 1988. Final report on propylene dichloride 13-week inhalation toxicity study with rats, mice and rabbits with cover letter dated 032888. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000399-1. FYI-OTS-0488-0399.
NOES. 1990. Estimated numbers of employees potentially exposed to specific agents by 2-digit standard industrial classification (SIC)*. National Occupational Exposure Survey (NOES).
NPIRS. 2017. Search Federal pesticide products: CAS 78-87-5, PC Code: 29001. West LaFayette, IN: National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/. March 28, 2017.
NTP. 1986. Toxicology and carcinogenesis studies of 1,2-dichloropropane (propylene dichloride) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. TR-263. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr263.pdf. December 1, 2016.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. April 13, 2016.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. October 2, 2015.
NTP. 2016. Report on carcinogens, 14th Ed. CASRN index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. February 28, 2017.
Odinecs A, Maso S, Nicoletto G, . 1995. Mechanism of sex-related differences in nephrotoxicity of 1.2-dichloropropane in rats. Ren Fail 17(5):517–524.8570864
OECD. 2006. 1,2-Dichloropropane. CAS No: 78-87-5. Organisation for Economic Co-operation and Development http://www.inchem.org/documents/sids/sids/78875.pdf. July 12, 2017.
Ogawa D, Hayashi H, Kitamura F, . 2020. Multiple cholangiocarcinomas in the intrahepatic and extrahepatic biliary tree due to dichloromethane exposure: a case report. Surg Case Rep 6(1):79. 10.1186/s40792-020-00842-9.32318894
Okamoto E, Kikuchi K, Endo G. 2013. Prevalence of bile duct cancer among printing industry workers in comparison with other industries. J Occup Health 55(6):511–515.24025857
O’Neil MJ, Heckelman PE, Dobbelaar PH, . 2013. Propylene dichloride. In: The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 15th ed. Whitehouse Station, NJ: The Royal Society of Chemistry, 7959–7960.
OSHA. 2020a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. September 28, 2020.
OSHA. 2020b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. September 28, 2020.
OSHA. 2020c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. September 28, 2020.
Parker CM, Coate WB, Voelker RW. 1982. Subchronic inhalation toxicity of 1,3-dichloropropene/1,2-dichloropropane (D-D) in mice and rats. J Toxicol Environ Health 9(5–6):899–910. 10.1080/15287398209530212.7120516
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16(11):781–785. 10.1021/es00105a010.22299786
Perbellini L, Zedde A, Schiavon R, . 1985. [Disseminated intravascular coagulation (DIC) caused by 1,2-dichloropropane (commercial trielin). Description of 2 cases]. Med Lav 76(5):412–417. (Italian)4088123
Perocco P, Bolognesi S, Alberghini W. 1983. Toxic activity of seventeen industrial solvents and halogenated compounds on human lymphocytes cultured in vitro. Toxicol Lett 16(1–2):69–75.6836616
Piet GJ, Morra CF. 1979. Behaviour of micropollutants in river water during bank filtration. In: Kuehn IW, Sontheimer H, eds. Oxidation techniques in drinking water treatment. Washington, DC: U.S. Environmental Protection Agency, 608–619. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=10003ESI.txt. December 5, 2016.
Pozzani U, Weil C, Carpenter C. 1959. The toxicological basis of threshold limit values: 5. The experimental inhalation of vapor mixtures by rats, with notes upon the relationship between single dose inhalation and single dose oral data. Am Ind Hyg Assoc J 20(5):364–369.14434607
Pozzi C, Marai P, Ponti R, . 1985. Toxicity in man due to stain removers containing 1,2-dichloropropane. Br J Ind Med 42(11):770–772.4063220
Principe P, Dogliotti E, Bignami M, . 1981. Mutagenicity of chemicals of industrial and agricultural relevance in Salmonella, Streptomyces and Aspergillus. J Sci Food Agric 32(8):826–832.7026896
Prival MJ, Dunkel VC. 1989. Reevaluation of the mutagenicity and carcinogenicity of chemicals previously identified as false positives in the salmonella typhimurium mutagenicity assay. Environ Mol Mutagen 13:1–24.2642804
Raijmakers MTM, Steegers EAP, Peters WHM. 2001. Glutathione S-transferases and thiol concentrations in embryonic and early fetal tissues. Hum Reprod 16(11):2445–2450.11679536
RePORTER. 2020. 1,2-Dichloropropane. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm.
Ritalahti KM, Loffler FE. 2004. Populations implicated in anaerobic reductive dechlorination of 1,2-dichloropropane in highly enriched bacterial communities. Appl Environ Microbiol 70(7):4088–4095. 10.1128/aem.70.7.4088-4095.2004.15240287
Roberts TR, Stoydin G. 1976. The degradation of (Z)-and (E)-1, 3-dichloropropenes and 1, 2-dichloropropane in soil. Pestic Sci 7(4):325–335.
Rohm & Haas De. Valley Inc. 1981. DCE, DCP and DCEE discharge data for Sept. 1981 from the Rohm and Haas Philadelphia plant’s discharges into the city sewer - with cover letter dated 100281. Rohm & Haas De. Valley Incorporated. Submitted to U.S. EPA under TSCA Section 4. OTS0511681. 40-8167035.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rowe BL, Toccalino PL, Moran MJ, . 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546. 10.1289/ehp.10253.18007981
Rubin DF. 1988. Occupational health implications of a toxic spill of propylene dichloride. West J Med 148(1):78–79.
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2(2):119–130. 10.1016/0734-242X(84)90135-6.
Santucci K, Shah B. 2000. Association of naphthalene with acute hemolytic anemia. Acad Emerg Med 7(1):42–47. 10.1111/j.1553-2712.2000.tb01889.x.10894241
Sato Y, Kubo S, Takemura S, . 2014. Different carcinogenic process in cholangiocarcinoma cases epidemically developing among workers of a printing company in Japan. Int J Clin Exp Pathol 7(8):4745–4754.25197345
Sawhney B, Pignatello J, Steinberg S. 1988. Determination of 1,2-dibromoethane (EDB) in field soils: Implications for volatile organic compounds. J Environ Qual 17(1):149–152.
SCDHS. 1983. Report on the occurrence and movement of agricultural chemicals in groundwater: South Fork of Suffolk County with cover letter dated 040183. Suffolk County Department of Health Services. Submitted to U.S. EPA under TSCA Section 4. OTS0511674. 40-8367029. 42043 B2-B28.
Schlotelburg C, Wintzingerode C, Hauck R, . 2002. Microbial structure of an anaerobic bioreactor population that continuously dechlorinates 1,2-dichloropropane. FEMS Microbiol Ecol 39(3):229–237. 10.1111/j.1574-6941.2002.tb00925.x.19709202
Secchi GC, Alessio L. 1968. [On the appearance of the mitochondrial isoenzyme of glutamic-oxalacetic transaminase in the serum of patients with acute toxic hepatopathy due to 1,2-dichloropropane and 1,2-dichloroethane]. Med Lav 59(11):649–653. (Italian)5734779
Sekiguchi S, Suda M, Zhai YL, . 2002. Effects of 1-bromopropane, 2-bromopropane, and 1,2-dichloropropane on the estrous cycle and ovulation in F344 rats. Toxicol Lett 126(1):41–49.11738269
Shackelford WM, Cline DM, Faas L, . 1983. An evaluation of automated spectrum matching for survey identification of wastewater components by gas chromatography - mass spectrometry. Anal Chim Acta 146:15–27. 10.1016/s0003-2670(00)80588-7.
Shell Oil Co. 1982. Toxicology of fine chemicals. The acute oral and percutaneous toxicity, skin and eye irritancy and skin sensitizing potential of 1,2-dichloropropane (light-ends). Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCATS, Section 8D. OTS0205965. 878212009.
Shell Oil Co. 1984. 1,2-Dichloropropane: An assessment of ready biodegradability with cover letter dated 103086. Shell Oil Company. Submitted to U.S. EPA under TSCA Section 8D. OTS0513371. 86870000025.
Shikiya J, Tsou G, Kowalski J, . 1984. Ambient monitoring of selected halogenated hydrocarbons and benzene in the California south coast air basin. 77th Annual meeting of the Air Pollution Control Association. Pittsburgh, PA: Air Pollution Control Association. Vol. 1, 84–111.
Sidorenko GI, Tsulaya VR, Korenevskaya EI, . 1976. Methodological approaches to the study of the combined effect of atmospheric pollutants as illustrated by chlorinated hydrocarbons. Environ Health Perspect 13:111–116.1269497
Sidorenko GI, Tsulaya VR, Bonashevskaya TI, . 1979. Study of the combined action of a group of chlorine derivatives of hydrocarbons entering the organism by inhalation. Environ Health Perspect 30:13–18.446444
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16(12):872–880. 10.1021/es00106a010.22236265
Singh HB, Salas L, Viezee W, . 1992. Measurement of volatile organic chemicals at selected sites in California. Atmos Environ 26(16):2929–2946.
Smyth HF, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data: List VII. Am Ind Hyg Assoc J 30(5):470–476. 10.1080/00028896909343157.5823428
Sobue T, Utada M, Makiuchi T, . 2015. Risk of bile duct cancer among printing workers exposed to 1,2-dichloropropane and/or dichloromethane. J Occup Health 57(3):230–236. 10.1539/joh.14-0116-OA.25739336
SRI. 1975. In vitro microbiological mutagenicity studies of ethyl compounds. Standford Research Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515770. 86-870001694.
Stolzenberg SJ, Hine CH. 1980. Mutagenicity of 2- and 3-carbon halogenated compounds in the Salmonella/mammalian-microsome test. Environ Mutagen 2(1):59–66.7035158
Sullivan DA, Jones AD, Williams JG. 1985. Results of the U.S. Environmental Protection Agency’s air toxic’s analysis in Philadelphia. 78th Annual meeting of the Air Pollution Control Association. Pittsburgh, PA: Air Pollution Control Association. Vol. 2, 1–15.
Suzuki T, Yanagiba Y, Suda M, . 2014. Assessment of the genotoxicity of 1,2-dichloropropane and dichloromethane after individual and co-exposure by inhalation in mice. J Occup Health 56(3):205–214.24739373
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Take M, Matsumoto M, Takeuchi T, . 2014. Inhalation exposure to 1,2-dichloropropane: Distribution of blood and tissue concentrations of 1,2-dichloropropane in rats during and after exposure. J Environ Sci Health A Tox Hazard Subst Environ Eng 49(12):1341–1348. 10.1080/10934529.2014.928193.25072765
Take M, Takeuchi T, Hirai S, . 2017. Distribution of 1,2-dichloropropane in blood and other tissues of rats after oral administration. J Toxicol Sci 42(2):121–128.28321038
Tennant RW, Margolin BH, Shelby MD, . 1987. Prediction of chemical carcinogenicity in rodents from in vitro genetic toxicity assays. Science 236(4804):933–941.3554512
Thomas RG. 1982. Volatilization from water. In: Lyman WH, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 15-11–15-34.
Thorel JM, Bercoff E, Massari P, . 1986. [Toxicity of 1,2-dichloropropane. A case with portal hypertension]. J Toxicol Clin Exp 6(4):247–252. (French)3783494
Timchalk C, Bartels MJ, Dryzga MD, . 1989. Propylene dichloride: Pharmacokinetics & metabolism in Fischer 344 rats following oral and inhalation exposure. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0527713. 40-8967188.
Timchalk C, Dryzga MD, Smith FA, . 1991. Disposition and metabolism of [^14^C]1,2-dichloropropane following oral and inhalation exposure in Fischer 344 rats. Toxicology 68(3):291–306.1897000
Tomimaru Y, Kobayashi S, Wada H, . 2015. Intrahepatic cholangiocarcinoma in a worker at an offset color proof-printing company: An autopsy case report. Hepatol Res 45(4):488–493. 10.1111/hepr.12363.24849871
Toyoda Y, Takada T, Suzuki H. 2016. Halogenated hydrocarbon solvent-related cholangiocarcinoma risk: biliary excretion of glutathione conjugates of 1,2-dichloropropane evidenced by untargeted metabolomics analysis. Sci Rep 6:24586. 10.1038/srep24586.27087417
Toyoda Y, Takada T, Suzuki H. 2017. Spontaneous production of glutathione-conjugated forms of 1,2-dichloropropane: Comparative study on metabolic activation processes of dihaloalkanes associated with occupational cholangiocarcinoma. Oxid Med Cell Longev 2017:9736836. 10.1155/2017/9736836.28555163
Toyooka T, Yanagiba Y, Suda M, . 2017. 1.2-Dichloropropane generates phosphorylated histone H2AX via cytochrome P450 2E1-mediated metabolism. Toxicol Lett 272:60–67.28300663
Trevisan A, Troso O, Maso S. 1991. Recovery of biochemical changes induced by 1,2-dichloro propane in rat liver and kidney. Hum Exp Toxicol 10(4):241–244.1679646
Trevisan A, Pozzobon L, Rizzi E, . 1988. [Behavior of the excretion of mercapturic acid after administration of 1,2-dichloropropane to the rat]. Med Lav 79(1):65–69. (Italian)3173224
Trevisan A, Rizzi E, Scapinello A, . 1989. Liver toxicity due to 1,2-dichloropropane in the rat. Arch Toxicol 63(6):445–449.2619558
Trevisan A, Meneghetti P, Maso S, . 1992. Sex- and age-related nephrotoxicity due to 1,2-dichloropropane in vitro. Arch Toxicol 66(9):641–645.1482287
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. February 10, 2020.
Umeda Y, Matsumoto M, Aiso S, . 2010. Inhalation carcinogenicity and toxicity of 1,2-dichloropropane in rats. Inhal Toxicol 22(13):1116–1126. 10.3109/08958378.2010.526973.21070183
USGS. 2003. National survey of methyl tert-butyl ether and other volatile organic compounds in drinking-water sources: Results of the random source-water survey. East Hartford, CT: U.S. Geological Survey. Water-Resources Investigations Report 2002-4079. https://pubs.usgs.gov/wri/2002/4079/report.pdf. August 3, 2017.
van Dijk H. 1980. Dissipation rates in soil of 1,2-dichloropropane and 1,3-and 2,3-dichloropropenes. Pestic Sci 11(6):625–632.
Vlaanderen J, Straif K, Pukkala E, . 2013. Occupational exposure to trichloroethylene and perchloroethylene and the risk of lymphoma, liver, and kidney cancer in four Nordic countries. Occup Environ Med 70(6):393–401. 10.1136/oemed-2012-101188.23447073
Vogt WG, Montague LY, Carrico PJ, . 1987. VOC emission rates from solid waste landfill. Proceedings of U.S. EPA Symposium on solid waste testing and quality assurance and testing. Washington, DC: July 13-17, 1987. Washington, DC: U.S. Environmental Protection Agency. 1–103 to 101–115. EPA530R87123. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101ZPFA.txt. October 8, 2020.
von der Hude W, Scheutwinkel M, Gramlich U, . 1987. Genotoxicity of three-carbon compounds evaluated in the SCE test in vitro. Environ Mutagen 9(4):401–410.3582297
von Der Hude W, Behm C, Guertler R, . 1988. Evaluation of the SOS chromotest. Mutat Res 203:81–94.3280989
Wang H, Chen J, Suda M, . 2019. Acute inhalation co-exposure to 1,2-dichloropropane and dichloromethane cause liver damage by inhibiting mitochondrial respiration and defense ability in mice. J Appl Toxicol 39(2):260–270. 10.1002/jat.3715.30240022
Welke B, Ettlinger K, Riederer M. 1998. Sorption of volatile organic chemicals in plant surfaces. Environ Sci Technol 32(8):1099–1104.
Weston RF. 1980. Characterization and fate of the discharge of priority pollutants from the Rohm and Haas Philadelphia plant in the Delaware. Rohm & Haas. Submitted to the U.S. Environmental Protections Agency under TSCA Section 8D. OTS0205979.
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Water Pollut Control Fed 76:52–59.
WHO. 1992. 1,3-Dichloropropene, 1,2-dichloropropane and mixtures health and safety guide. Geneva: World Health Organization. Health and Safety Guide No. 76.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Woodruff RC, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in Drosophila. V. Results of 53 coded compounds tested for the National Toxicology Program. Environ Mutagen 7(5):677–702.3930237
WQP. 2017a. 1,2-Dichloropropane. STORET 1988-2010. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. July 31, 2017.
WQP. 2017b. 1,2-Dichloropropane. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. March 27, 2017.
Yamada K, Kumagai S, Nagoya T, . 2014. Chemical exposure levels in printing workers with cholangiocarcinoma. J Occup Health 56(5):332–338.25069896
Yamada K, Kumagai S, Endo G. 2015a. Chemical exposure levels in printing workers with cholangiocarcinoma (second report). J Occup Health 57(3):245–252. 10.1539/joh.14-0239-OA.25739405
Yamada K, Kumagai S, Kubo S, . 2015b. Chemical exposure levels in printing and coating workers with cholangiocarcinoma (third report). J Occup Health 57(6):565–571. 10.1539/joh.15-0170-OA.26447094
Yanagiba Y, Suzuki T, Suda M, . 2016. Cytochrome P450 2E1 is responsible for the initiation of 1,2-dichloropropane-induced liver damage. Toxicol Ind Health 32(9):1589–1597. 10.1177/0748233714568801.25681370
Yasunaga K, Kiyonari A, Oikawa T, . 2004. Evaluation of the Salmonella umu test with 83 NTP chemicals. Environ Mol Mutagen 44(4):329–345. 10.1002/em.20053.15476194
Zeiger E. 1987. Carcinogenicity of mutagens: predictive capability of the Salmonella mutagenesis assay for rodent carcinogenicity. Cancer Res 47(5):1287–1296.3815340
Zhang L, Zong C, Ichihara S, . 2015. A trial to find appropriate animal models of dichloropropane-induced cholangiocarcinoma based on the hepatic distribution of glutathione S-transferases. J Occup Health 57(6):548–554. 10.1539/joh.15-0085-OA.26423826
Zhang X, Zong C, Zhang L, . 2018. Exposure of mice to 1,2-dichloropropane induces CYP450-dependent proliferation and apoptosis of cholangiocytes. Toxicol Sci 162(2):559–569. 10.1093/toxsci/kfx272.29228347
Zhang X, Morikawa K, Mori Y, . 2020. Proteomic analysis of liver proteins of mice exposed to 1,2-dichloropropane. Arch Toxicol 94:2691–2705. 10.1007/s00204-020-02785-4.32435916
Zong C, Kimura Y, Kinoshita K, . 2019. Exposure to 1,2-dichloropropane upregulates the expression of activation-induced cytidine deaminase (AID) in human cholangiocytes co-cultured with macrophages. Toxicol Sci 168(1):137–148. 10.1093/toxsci/kfy280.30452740