# VERSION HISTORY

Date | Description
November 2021 | Final toxicological profile released
December 2019 | Draft for public comment toxicological profile released
December 1989 | Final toxicological profile released