# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-dichloropropane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-dichloropropane.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Dichloropropane

Agency | Description | Information | Reference
Air
EPA | RfC | 4x10^-3^ mg/m^3^ (0.0009 ppm) | EPA 1991
EPA | Provisional peer reviewed toxicity values
EPA | Provisional subchronic RfC | 4x10^-3^ mg/m^3^ (0.0009 ppm) | EPA 2016a
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.09 mg/L | EPA 2018a
EPA | 10^-4^ Cancer risk | 0.06 mg/L | EPA 2018a
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.005 mg/L | EPA 2009
EPA | RfD | Not evaluated | EPA 1991
EPA | Provisional peer reviewed toxicity values | | EPA 2016a
EPA | Provisional chronic and subchronic RfD | 4x10^-2^ mg/kg/day | EPA 2016a
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Provisional guideline value | 0.04 mg/L | WHO 2017
WHO | TDI | 14 μg/kg body weight | WHO 2017
FDA | Substances added to food^a^ | No data | FDA 2020
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Provisional peer reviewed toxicity values | | EPA 2016a
EPA | Carcinogenicity classification | Likely to be carcinogenic to humans | EPA 2016a
EPA | Provisional inhalation unit risk | 3.7x10^−3^ (mg/m^3^)^−1^ | EPA 2016a
EPA | Provisional oral slope factor | 3.7x10^−2^ (mg/kg/day)^−1^ | EPA 2016a
IARC | Carcinogenicity classification | Group 1^b^ | IARC 2017
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 75 ppm (350 mg/m^3^) | OSHA 2020a, 2020b, 2020c
NIOSH | REL (up to 10-hour TWA) | Ca^c^ | NIOSH 2019
NIOSH | IDLH | 400 ppm^c^ | NIOSH 2014
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^d^ | 30 ppm | DOE 2018a
DOE | PAC-2^d^ | 220 ppm | DOE 2018a
DOE | PAC-3^d^ | 2,000 ppm | DOE 2018a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b Group 1: carcinogenic to humans.

c Potential occupational carcinogen.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = U.S. Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TDI = tolerable daily intake; TWA = time-weighted average; WHO = World Health Organization