# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,2-dichloropropane are listed in Table 4-1.

Table 4-1 Chemical Identity of 1,2-Dichloropropane

Characteristic | Information | Reference
Chemical name | 1,2-Dichloropropane | MacBean 2010
Synonym(s) | Propylene dichloride; propylene chloride; PDC; dichloro-1,2- propane; DCP; alpha, beta-dichloropropane; alpha, beta propylene dichloride; dichloropropane | ChemIDplus 2017; MacBean 2010; OECD 2006
Registered trade name(s) | Nematox; Vidden D; Dowfume EB-5; 1,2-D; D-D; Telone; Telone II; Component of: D-D Mixture; Nemex; Vidden D; Vorlex | Ali et al. 1986; Bennett 1981; EPA 1995; NPIRS 2017; OECD 2006
Chemical formula | C_3_H_6_C_l2_ | MacBean 2010
Chemical structure | Chemical structure | ChemIDplus 2017
Identification numbers:
CAS Registry Number | 78-87-5; 26198-63-0 racemic mixture | ChemIDplus 2017; Haynes et al. 2014

a Includes names of those products which contain 1,2-dichloropropane in a mixture of compounds.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,2-dichloropropane are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,2-Dichloropropane

Property | Information | Reference
Molecular weight | 112.98 | O’Neil et al. 2013
Color | Colorless | OECD 2006
Physical state | Liquid | Haynes et al. 2014
Melting point | −100.44°C; Freezes at −70°C | Langer et al. 2011; MacBean 2010
Boiling point | 96.3°C | Larranga et al. 2016
Density at 20°C | 1.1583 | Larranga et al. 2016
Odor | Chloroform-like | Larranga et al. 2016
Odor threshold:
Water | 0.010 ppm (w/v) | Amoore and Hautala 1983
Air | 0.25 ppm (v/v) | Amoore and Hautala 1983
Solubility:
Water at 20°C | 2,700 mg/L | MacBean 2010
Water at 25°C | 2,800 mg/L | Horvath 1982
Organic solvents | Soluble in ethanol, diethyl ether, benzene, and chloroform | Haynes et al. 2014
Partition coefficients:
Log K_ow_ | 1.98 | EPA 2012
Log K_ow_ | 2.28 | MacBean 2010
Log K_oc_ | 1.67 | EPA 2012
Vapor pressure at 20°C | 53.3 mm Hg (25°C) | EPA 2012
Henry’s law constant at 25°C | 2.82x10^-3^ at 25°C; 2.07x10^-3^ atm-m^3^/mol (24°C); 1.67x10^-3^ atm-m^3^/mol (24°C) | EPA 1987a; Mackay and Yeun 1983; Chiou et al. 1980
Autoignition temperature | 557°C | Larranga et al. 2016
Flashpoint | 16.1°C; 21°C (open cup) | Larranga et al. 2016; O’Neil et al. 2013
Conversion factors | 1 mg/m^3^=0.21 ppm (v/v)
Explosive limits | In air: 3.4–14.5 vol % | Langer et al. 2011