# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR 1,2-DICHLOROPROPANE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to 1,2-dichloropropane, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to 1,2-dichloropropane:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 1,2-dichloropropane. The inclusion criteria used to identify relevant studies examining the health effects of 1,2-dichloropropane are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

- Species; - Human; - Laboratory mammals
- Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
- Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of 1,2-dichloropropane. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for 1,2-dichloropropane released for public comment in 2019. See Appendix B for the databases searched and the search strategy.

A total of 368 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of 1,2-dichloropropane.

Title and Abstract Screen. In the Title and Abstract Screen step, 368 records were reviewed; 8 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 72 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 72 documents, 121 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for 1,2-dichloropropane and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-2, 2-3, and 2-4, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for 1,2-dichloropropane identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The only available human studies evaluating noncancer effects are limited to case reports of accidental or intentional exposure. However, when evaluated together, these studies indicate that hematological, hepatic, renal, and neurological systems are susceptible to 1,2-dichloropropane toxicity. Animal studies examined a comprehensive set of endpoints following inhalation or oral exposure, but dermal studies were limited to acute lethality, skin irritation, and skin sensitization. Respiratory, hematological, hepatic, renal, neurological, and developmental effects were considered sensitive outcomes, i.e., effects were observed at low concentrations or doses. Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 121 studies (published in 72 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Substance 1,2-Dichloropropane Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | | | | 1 | | | | | | | | | | | | 5
Cohort | | | | | | | | | | | | | | | | | 5
Case control | | | | | | | | | | | | 1
Case control
Population
Population
Case series/reports | | 1 | | 2 | 2 | | 3 | 1 | | 1 | | | 2 | 1 | | | 11
Case series/reports | | 1 | | 2 | 2 | | 3 | 1 | | 1 | | | 2 | 1 | | | 11
Oral studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series/reports | | | 3 | | 3 | | 5 | 2 | | | | | 2
Case series/reports | | | 3 | | 3 | | 5 | 2 | | | | | 2
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series/reports | | | 1 | 1 | 1 | 1 | 1 | 1 | 3 | | | 2
Case series/reports | | | 1 | 1 | 1 | 1 | 1 | 1 | 3 | | | 2
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-4 Overview of the Health Outcomes for 1,2-Dichloropropane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 9 | 5 | 5 | | 5 | | 27 | 16 | | 1 | 10 | 3 | 9 | 3
Acute-duration | 3 | 5 | | | 3 | | 17 | 8 | | 1 | 5 | 1 | 8
Intermediate-duration | 10 | 5 | 12 | 5 | 12 | 3 | 14 | 12 | 3 | 3 | 7 | 5 | 6 | 6 | | | 1
Intermediate-duration | 6 | 4 | 2 | 1 | 10 | | 8 | 3 | | | 3 | | 1 | 1 | | | 1
Chronic-duration | 2 | 2 | 2 | 2 | 2 | | 2 | 2 | 1 | | 2 | 2 | 2 | 2 | | | 2
Chronic-duration | 2 | | | | 1 | | | | | | | | | | | | 2
Oral studies
Acute-duration | 10 | 3 | | 2 | 8 | | 13 | 12 | | | 1 | | 8 | 6 | 2
Acute-duration | 7 | | | 1 | 4 | | 8 | | | | | | 7 | 2 | 2
Intermediate-duration | 7 | 5 | 2 | 3 | 6 | 2 | 6 | 6 | 2 | 1 | 3 | 2 | 4 | 4 | 1 | | 1
Intermediate-duration | 4 | | | | 2 | | 5 | | | | 1 | | 1 | 1 | 1
Chronic-duration | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | | 2 | 2 | 2 | 2 | | | 2
Chronic-duration | 1 | | | 1 | | | 2 | | | | | | | | | | 2
Dermal studies
Acute-duration | 2 | | | | | | | | 4 | | | 1
Acute-duration | | | | | | | | | 4 | | | 1
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes studies evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; - Were the comparison groups appropriate?
Confounding bias; - Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for human observational studies and animal experimental studies are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for 1,2-Dichloropropane —Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Comparison groups appropriate? | Study design or analysis account for important confounding and modifying variables?* | Outcome data complete without attrition or exclusion from analysis? | Confidence in exposure characterization?* | Confidence in outcome assessment?* | All measured outcomes reported? | Risk of bias tier
Outcome: Upper respiratory effects
Inhalation—case reports
Rubin 1988 | − − | − − | − | − − | + | − | Third
Outcome: Hematological Effects
Inhalation – retrospective cohort
Kumagai et al. 2013, 2014 | ++ | − | + | − − | + | ++ | Third
Inhalation—case reports
Lucantoni et al. 1991, 1992 | − − | − − | − | − − | + | − | Third
Pozzi et al. 1985 | − − | − − | − | − − | + | −
Oral—case reports
Di Nucci et al. 1988 | − − | − − | − | − − | + | − | Third
Perbellini et al. 1985 | − − | − − | − | − − | + | − | Third
Pozzi et al. 1985 | − − | − − | − | − − | + | − | Third
Dermal—case reports
Fiaccadori et al. 2003 | − − | − − | − | − − | + | − | Third
Outcome: Hepatic Effects
Inhalation—case reports
Lucantoni et al. 1991, 1992 | − − | − − | − | − − | + | − | Third
Pozzi et al. 1985 | − − | − − | − | − − | + | − | Third
Kubo et al. 2015 | − − | − − | − | − − | + | − | Third
Oral—case reports | | | | | | | Third
Chiappino and Secchi 1968 | − − | − − | − | − − | + | − | Third
Di Nucci et al. 1988 | − − | − − | − | − − | + | − | Third
Larcan et al. 1977 | − − | − − | − | − − | + | − | Third
Perbellini et al. 1985 | − − | − − | − | − − | + | − | Third
Pozzi et al. 1985 | − − | − − | − | − − | + | − | Third
Secchi and Alessio 1968 | − − | − − | − | − − | + | − | Third
Thorel et al. 1986 | − − | − − | − | − − | + | − | Third
Dermal—case reports
Fiaccadori et al. 2003 | − − | − − | − | − − | + | − | Third
Outcome: Renal Effects
Inhalation—case reports
Pozzi et al. 1985 | − − | − − | − | − − | + | − | Third
Oral—case reports
Di Nucci et al. 1988 | − − | − − | − | − − | + | − | Third
Perbellini et al. 1985 | − − | − − | − | − − | + | − | Third
Pozzi et al. 1985 | − − | − − | − | − − | + | − | Third
Dermal—case reports
Fiaccadori et al. 2003 | − − | − − | − | − − | + | − | Third
Outcome: CNS Depression
Inhalation—case reports
Kwack et al. 2018 | − − | − − | + | − | + | + | Third
Rubin 1988 | − − | − − | − | − − | + | − | Third
Oral—case reports
Larcan et al. 1977 | − − | − − | − | − − | + | − | Third
Perbellini et al. 1985 | − − | − − | − | − − | + | − | Third

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

Table C-9 Summary of Risk of Bias Assessment for 1,2-Dichloropropane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Upper Respiratory Effects
Inhalation acute exposure
Nitschke and Johnson 1983 (rat; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (rabbit; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation intermediate exposure
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Outcome: Hematological Effects
Inhalation acute exposure
Heppel et al. 1946b (rat; 5–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (guinea pig; 5 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit; 2–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Nitschke and Johnson 1983 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation intermediate exposure
Heppel et al. 1946b (dog) | − | − | ++ | − | + | − | − | + | NA | Third
Heppel et al. 1946b (rat) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1948 (dog) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rat) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (mouse) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (guinea pig) | − | + | + | + | + | − | − | + | NA | Second
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Oral acute exposure
Berdasco et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gorzinski and Johnson 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Imberti et al. 1990 (rat) | − | − | − − | − | + | ++ | − | + | NA | Third
Kirk et al. 1989 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rabbit) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral intermediate exposure
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1990 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral chronic exposure
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Outcome: Hepatic Effects
Inhalation acute exposure
Di Nucci et al. 1990 (rat) | − | + | + | + | ++ | − | − | ++ | NA | Second
Drew et al. 1978 (rat) | − | + | + | + | ++ | + | − | ++ | NA | Second
Heppel et al. 1946a (rat; 7 hours) | − − | − − | − − | − − | + | − | − − | + | NA | Third
Heppel et al. 1946a (rat; 5–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (mouse; 2–7 hours) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit; 2–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (guinea pig; 5 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rat) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (mouse) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (guinea pig) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (rat; 5 days) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (guinea pig; 7 hours) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (guinea pig; 2–3 days) | − | + | + | + | + | − | − | + | NA | Second
Nitschke and Johnson 1983 (rat; 6 hours) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (rat; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse; 6 hours) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (rabbit; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Toyooka et al. 2017 (mouse) | − | + | ++ | + | ++ | ++ | + | ++ | NA | First
Wang et al. 2019 (mouse, up to 4 hours) | − | + | ++ | + | ++ | + | ++ | + | NA | First
Wang et al. 2019 (mouse, 6 hours) | − | + | ++ | + | ++ | + | ++ | + | NA | First
Zhang et al. 2015 (rat, 7 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (C57BL/6 mouse; 7 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (BALB mouse; 7 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (mouse; 14 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (hamster; 7 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (hamster; 14 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Zhang et al. 2015 (guinea pig; 7 days) | − | + | + | + | + | ++ | ++ | ++ | NA | First
Inhalation intermediate exposure
Heppel et al. 1946a (dog) | − | − | ++ | − | + | − | − | + | NA | Third
Heppel et al. 1946a (rat) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (guinea pig) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1948 (dog) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rat) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (mouse) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (guinea pig) | − | + | + | + | + | − | − | + | NA | Second
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Zhang et al. 2018 (mouse) | + | + | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Oral acute exposure
Berdasco et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Di Nucci et al. 1988 (rat) | − | + | + | + | ++ | − | − | ++ | NA | Second
Gi et al. 2015a (mouse; once) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster; once) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gorzinski and Johnson 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Imberti et al. 1990 (rat) | − | − | − − | − | + | ++ | − | + | NA | Third
Kirk et al. 1988 (rabbit) | − | − | ++ | − | ++ | ++ | + | ++ | NA | First
Kirk et al. 1989 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rabbit) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral intermediate exposure
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1990 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral chronic exposure
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Outcome: Renal Effects
Inhalation acute exposure
Heppel et al. 1946a (rat; 5–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (mouse; 2–7 hours) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit; 2–8 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (guinea pig; 5 days) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rat) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (mouse) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (guinea pig) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (rat; 5 days) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (guinea pig; 7 hours) | − | + | + | + | + | − | − | + | NA | Second
Highman and Heppel 1946 (guinea pig; 2–3 days) | − | + | + | + | + | − | − | + | NA | Second
Nitschke and Johnson 1983 (rat; 6 hours) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (rat; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse; 6 hours) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (mouse; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke and Johnson 1983 (rabbit; 2 weeks) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation intermediate exposure
Heppel et al. 1946a (dog) | − | − | ++ | − | + | − | − | + | NA | Third
Heppel et al. 1946a (rat) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (rabbit) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1946a (guinea pig) | − | + | ++ | + | + | − | − | + | NA | Second
Heppel et al. 1948 (dog) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rat) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (mouse) | − | + | + | + | + | − | − | + | NA | Second
Heppel et al. 1948 (rabbit) | − | + | + | + | + | − | − | + | NA | Second
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Nitschke et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Umeda et al. 2010 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Oral acute exposure
Berdasco et al. 1988 (rabbit) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster; 4 days) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gorzinski and Johnson 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Imberti et al. 1990 (rat) | − | − | − − | − | + | ++ | − | + | NA | Third
Kirk et al. 1988 (rabbit) | − | − | ++ | − | ++ | ++ | + | ++ | NA | First
Kirk et al. 1989 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rabbit) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (rat) | + | + | ++ | + | ++ | ++ | ++ | + | NA | First
NTP 1986 (mouse) | + | + | ++ | + | ++ | ++ | ++ | + | NA | First
Oral intermediate exposure
Bruckner et al. 1989 (rat) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (mouse) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Gi et al. 2015a (hamster) | − | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1990 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral chronic exposure
NTP 1986 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
NTP 1986 (mouse) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Outcome: CNS Depression
Inhalation acute exposure
Heppel et al. 1946a (rat; 7 hours) | − − | − − | − − | − − | + | − | − | + | NA | Third
Heppel et al. 1946a (rat; 5–8 days) | − | − | ++ | − | + | − | − | + | NA | Third
Heppel et al. 1946a (mouse; 2–7 hours) | − | − | ++ | − | + | − | − | + | NA | Third
Heppel et al. 1946a (guinea pig; 5 days) | − | − | ++ | − | + | − | − | + | NA | Third
Nitschke and Johnson 1983 (rat; 6 hours) | ++ | + | ++ | + | + | ++ | ++ | + | NA | First
Nitschke and Johnson 1983 (mouse; 6 hours) | ++ | + | ++ | + | + | ++ | ++ | + | NA | First
Sidorenko et al. 1979 (rat) | − | − | − | − | − | − | − | − | NA | Third
Sidorenko et al. 1976 (mouse) | − | − | − | − | − | − | − | − | NA | Third
Inhalation intermediate exposure
Sidorenko et al. 1979 (rat) | − | − | − | − | − | − | − | − | NA | Third
Oral acute exposure
Bruckner et al. 1989 (rat) | + | − | ++ | − | ++ | ++ | ++ | ++ | NA | First
Exxon 1981a (rat) | ++ | − | ++ | − | − | ++ | + | ++ | NA | First
Gorzinski and Johnson 1989 (rat) | + | − | ++ | − | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1988 (rabbit) | − | − | ++ | − | ++ | ++ | + | ++ | NA | First
Kirk et al. 1989 (rat) | ++ | − | ++ | − | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rabbit) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Shell Oil Co. 1982 (rat) | − | − | ++ | − | ++ | − | + | ++ | NA | Second
Oral intermediate exposure
Bruckner et al. 1989 (rat) | + | − | ++ | − | ++ | ++ | ++ | ++ | NA | First
Johnson and Gorzinski 1988 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Outcome: Developmental Effects
Oral acute exposure
Kirk et al. 1995 (rat) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Kirk et al. 1995 (rabbit) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | NA | First
Oral intermediate exposure
Kirk et al. 1990 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to 1,2-dichloropropane and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to 1,2-dichloropropane and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus selfreported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining upper respiratory, hematological, hepatic, renal, neurological, and developmental effects observed in human observational studies and animal experimental studies are presented in Tables C-13 and C-14, respectively.

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence.

Table C-13 Presence of Key Features of Study Design for 1,2-Dichloropropane—Observational Epidemiology Studies

Reference | Key feature | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Upper respiratory effects
Inhalation—case reports
Rubin 1988 | No | Yes | Yes | No | Low
Outcome: Hematological Effects
Inhalation—retrospective cohort
Kumagai et al. 2013, 2014 | No | Yes | Yes | Yes | Moderate
Inhalation—case reports
Lucantoni et al. 1991, 1992 | No | Yes | Yes | No | Low
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Oral—case reports
Di Nucci et al. 1988 | No | Yes | Yes | No | Low
Perbellini et al. 1985 | No | Yes | Yes | No | Low
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Dermal—case reports
Fiaccadori et al. 2003 | No | Yes | Yes | No | Low
Outcome: Hepatic Effects
Inhalation—case reports
Lucantoni et al. 1991, 1992 | No | Yes | Yes | No | Low
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Kubo et al. 2015 | No | Yes | Yes | No | Low
Oral—case reports
Chiappino and Secchi 1968 | No | Yes | Yes | No | Low
Di Nucci et al. 1988 | No | Yes | Yes | No | Low
Larcan et al. 1977 | No | Yes | Yes | No | Low
Perbellini et al. 1985 | No | Yes | Yes | No | Low
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Secchi and Alessio 1968 | No | Yes | Yes | No | Low
Thorel et al. 1986 | No | Yes | Yes | No | Low
Dermal—case reports
Fiaccadori et al. 2003 | No | Yes | Yes | No | Low
Outcome: Renal Effects
Inhalation—case reports
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Oral—case reports
Di Nucci et al. 1988 | No | Yes | Yes | No | Low
Perbellini et al. 1985 | No | Yes | Yes | No | Low
Pozzi et al. 1985 | No | Yes | Yes | No | Low
Dermal—case reports
Fiaccadori et al. 2003 | No | Yes | Yes | No | Low
Outcome: CNS Depression
Inhalation—case reports
Kwack et al. 2018 | No | Yes | Yes | No | Low
Rubin 1988 | No | Yes | Yes | No | Low
Oral—case reports
Larcan et al. 1977 | No | Yes | Yes | No | Low
Perbellini et al. 1985 | No | Yes | Yes | No | Low

Table C-14 Presence of Key Features of Study Design for 1,2-Dichloropropane—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Upper Respiratory Effects
Inhalation acute exposure
Nitschke and Johnson 1983 (rat; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rat) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rabbit) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Hematological Effects
Inhalation acute exposure
Heppel et al. 1946b (rat; 5–8 days) | No | Yes | No | No | Very Low
Heppel et al. 1946a (guinea pig; 5 days) | No | Yes | No | No | Very Low
Heppel et al. 1946a (rabbit; 2–8 days) | No | No | No | No | Very Low
Nitschke and Johnson 1983 (rat; 2 weeks) | Yes | Yes | Yes | Yes | High
Nitschke and Johnson 1983 (mouse; 2 weeks) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Heppel et al. 1946b (dog) | Yes | No | Yes | No | Low
Heppel et al. 1946b (rat) | Yes | Yes | No | No | Low
Heppel et al. 1946a (rabbit) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (dog) | Yes | Yes | No | No | Low
Heppel et al. 1948 (rat) | Yes | Yes | No | No | Low
Heppel et al. 1948 (mouse) | Yes | Yes | No | No | Low
Heppel et al. 1946a (guinea pig) | Yes | Yes | No | No | Low
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rat) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rabbit) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | No | Moderate
Umeda et al. 2010 (rat) | Yes | Yes | Yes | No | Moderate
Oral acute exposure
Berdasco et al. 1988 (rabbit) | Yes | Yes | Yes | Yes | High
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | No | Moderate
Gi et al. 2015a (rat) | Yes | Yes | No | Yes | Moderate
Gi et al. 2015a (hamster) | Yes | Yes | No | Yes | Moderate
Gorzinski and Johnson 1989 (rat) | Yes | Yes | Yes | Yes | High
Imberti et al. 1990 (rat) | No | Yes | Yes | No | Low
Kirk et al. 1989 (rat) | Yes | Yes | Yes | Yes | High
Kirk et al. 1995 (rabbit) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (mouse) | Yes | Yes | No | Yes | Moderate
Gi et al. 2015a (hamster) | Yes | Yes | Yes | Yes | High
Kirk et al. 1990 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (rat) | Yes | Yes | No | Yes | Moderate
NTP 1986 (mouse) | Yes | Yes | No | Yes | Moderate
Oral chronic exposure
NTP 1986 (rat) | Yes | Yes | No | Yes | Moderate
NTP 1986 (mouse) | Yes | Yes | No | Yes | Moderate
Outcome: Hepatic Effects
Inhalation acute exposure
Di Nucci et al. 1990 (rat) | Yes | Yes | No | No | Low
Drew et al. 1978 (rat) | Yes | Yes | No | No | Low
Heppel et al. 1946a (rat; 7 hours) | No | No | Yes | No | Very Low
Heppel et al. 1946a (rat; 5–8 days) | No | Yes | Yes | No | Low
Heppel et al. 1946a (mouse; 2–7 hours) | No | Yes | Yes | No | Low
Heppel et al. 1946a (rabbit; 2–8 days) | No | No | Yes | No | Very Low
Heppel et al. 1946a (guinea pig; 5 days) | No | Yes | Yes | No | Low
Heppel et al. 1948 (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (mouse) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (guinea pig) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (rat; 5 days) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (guinea pig; 7 hours) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (guinea pig; 2–3 days) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rat; 6 hours) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rat; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Yes | Yes | Yes | No | Moderate
Toyooka et al. 2017 | Yes | NR | No | No | Very Low
Wang et al. 2019 (mouse, up to 4 hours) | Yes | Yes | Yes | Yes | High
Wang et al. 2019 (mouse, 6 hours) | Yes | Yes | Yes | Yes | High
Zhang et al. 2015 (rat; 7 days) | Yes | No | Yes | No | Low
Zhang et al. 2015 (C57BL/6 mouse; 7 days) | Yes | No | Yes | No | Low
Zhang et al. 2015 (BALB mouse; 7 days) | Yes | No | Yes | No | Low
Zhang et al. 2015 (mouse; 14 days) | Yes | Yes | Yes | No | Moderate
Zhang et al. 2015 (hamster; 7 days) | Yes | No | Yes | No | Low
Zhang et al. 2015 (hamster; 14 days) | Yes | Yes | Yes | No | Moderate
Zhang et al. 2015 (guinea pig; 7 days) | Yes | No | Yes | No | Low
Inhalation intermediate exposure
Heppel et al. 1946a (dog) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (rabbit) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (guinea pig) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (dog) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (mouse) | Yes | Yes | Yes | No | Moderate
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rat) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rabbit) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Zhang et al. 2018 (mouse) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Berdasco et al. 1988 (rabbit) | Yes | Yes | No | Yes | Moderate
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | Yes | High
Di Nucci et al. 1990 (rat) | Yes | Yes | No | Yes | Moderate
Gi et al. 2015a (mouse; once) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (mouse; 4 days) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (hamster; once) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (hamster; 4 days) | Yes | Yes | Yes | Yes | High
Gorzinski and Johnson 1989 (rat) | Yes | Yes | Yes | Yes | High
Imberti et al. 1990 (rat) | No | Yes | No | No | Very Low
Kirk et al. 1988 (rabbit) | Yes | No | Yes | Yes | Moderate
Kirk et al. 1989 (rat) | Yes | Yes | No | Yes | Moderate
Kirk et al. 1995 (rat) | Yes | Yes | No | Yes | Moderate
Kirk et al. 1995 (rabbit) | Yes | Yes | No | Yes | Moderate
Oral intermediate exposure
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (mouse) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (hamster) | Yes | Yes | Yes | Yes | High
Kirk et al. 1990 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (mouse) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NTP 1986 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (mouse) | Yes | Yes | Yes | Yes | High
Outcome: Renal Effects
Inhalation acute exposure
Heppel et al. 1946a (rat; 5–8 days) | No | Yes | Yes | No | Low
Heppel et al. 1946a (mouse; 2–7 hours) | No | Yes | Yes | No | Low
Heppel et al. 1946a (rabbit; 2–8 days) | No | No | Yes | No | Very Low
Heppel et al. 1946a (guinea pig; 5 days) | No | Yes | Yes | No | Low
Heppel et al. 1948 (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (mouse) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (guinea pig) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (rat; 5 days) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (guinea pig; 7 hours) | Yes | Yes | Yes | No | Moderate
Highman and Heppel 1946 (guinea pig; 2–3 days) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rat; 6 hours) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rat; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
Heppel et al. 1946a (dog) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (rabbit) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1946a (guinea pig) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (dog) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (rat) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (mouse) | Yes | Yes | Yes | No | Moderate
Heppel et al. 1948 (guinea pig) | Yes | Yes | Yes | No | Moderate
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rat) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Nitschke et al. 1988 (rabbit) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
Matsumoto et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Umeda et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Berdasco et al. 1988 (rabbit) | Yes | Yes | No | Yes | Moderate
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | No | Moderate
Gi et al. 2015a (mouse; 4 days) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (hamster; 4 days) | Yes | Yes | Yes | Yes | High
Gorzinski and Johnson 1989 (rat) | Yes | Yes | Yes | Yes | High
Imberti et al. 1990 (rat) | No | Yes | No | No | Very Low
Kirk et al. 1988 (rabbit) | Yes | No | Yes | Yes | Moderate
Kirk et al. 1989 (rat) | Yes | Yes | No | Yes | Moderate
Kirk et al. 1995 (rat) | Yes | Yes | No | Yes | Moderate
Kirk et al. 1995 (rabbit) | Yes | Yes | No | Yes | Moderate
NTP 1986 (rat) | Yes | Yes | No | Yes | Moderate
NTP 1986 (mouse) | Yes | Yes | No | Yes | Moderate
Oral intermediate exposure
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | No | Moderate
Gi et al. 2015a (mouse) | Yes | Yes | Yes | Yes | High
Gi et al. 2015a (hamster) | Yes | Yes | Yes | Yes | High
Kirk et al. 1990 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (mouse) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NTP 1986 (rat) | Yes | Yes | Yes | Yes | High
NTP 1986 (mouse) | Yes | Yes | Yes | Yes | High
Outcome: CNS Depression
Inhalation acute exposure
Heppel et al. 1946a (rat; 7 hours) | No | Yes | Yes | No | Low
Heppel et al. 1946a (rat; 5–8 days) | No | Yes | Yes | No | Low
Heppel et al. 1946a (mouse; 2–7 hours) | No | Yes | Yes | No | Low
Heppel et al. 1946a (guinea pig; 5 days) | No | Yes | Yes | No | Low
Nitschke and Johnson 1983 (rat; 6 hours) | Yes | Yes | Yes | No | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Yes | Yes | Yes | No | Moderate
Sidorenko et al. 1979 (rat) | Yes | NR | NR | No | Very low
Sidorenko et al. 1976 (mouse) | No | NR | Yes | No | Very low
Inhalation intermediate exposure
Sidorenko et al. 1979 (rat) | Yes | NR | NR | No | Very low
Oral acute exposure
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | No | Moderate
Exxon 1981a (rat) | No | Yes | Yes | No | Low
Gorzinski and Johnson 1989 (rat) | Yes | Yes | Yes | Yes | High
Kirk et al. 1988 (rabbit) | Yes | No | Yes | Yes | Moderate
Kirk et al. 1989 (rat) | Yes | Yes | Yes | Yes | High
Kirk et al. 1995 (rat) | Yes | Yes | Yes | No | Moderate
Kirk et al. 1995 (rabbit) | Yes | Yes | Yes | No | Moderate
Shell Oil Co. 1982 (rat) | No | Yes | Yes | Yes | Moderate
Oral intermediate exposure
Bruckner et al. 1989 (rat) | Yes | Yes | Yes | No | Moderate
Johnson and Gorzinski 1988 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Developmental Effects
Oral acute exposure
Kirk et al. 1995 (rat) | Yes | Yes | Yes | Yes | High
Kirk et al. 1995 (rabbit) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Kirk et al. 1990 (rat) | Yes | Yes | No | Yes | Moderate

NR = not reported

Table C-15 Initial Confidence Rating for 1,2-Dichloropropane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Upper Respiratory Effects
Inhalation acute exposure
Human studies
Rubin 1988 | Low | Low
Inhalation acute exposure
Nitschke and Johnson 1983 (rat; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
Matsumoto et al. 2013 (mouse) | High | High
Nitschke et al. 1988 (rat) | High | High
Nitschke et al. 1988 (mouse) | High | High
Nitschke et al. 1988 (rabbit) | High | High
Umeda et al. 2010 (rat) | High | High
Inhalation chronic exposure
Animal studies
Matsumoto et al. 2013 (mouse) | High | High
Umeda et al. 2010 (rat) | High | High
Outcome: Hematological Effects
Inhalation acute exposure
Human Studies
Lucantoni et al. 1991, 1992 | Low | Low
Pozzi et al. 1985 | Low | Low
Animal studies
Heppel et al. 1946b (rat; 5–8 days) | Very Low | High
Heppel et al. 1946a (guinea pig; 5 days) | Very Low | High
Heppel et al. 1946a (rabbit; 2–8 days) | Very Low | High
Nitschke and Johnson 1983 (rat; 2 weeks) | High | High
Nitschke and Johnson 1983 (mouse; 2 weeks) | High | High
Inhalation intermediate exposure
Animal studies
Heppel et al. 1946b (dog) | Low | High
Heppel et al. 1946b (rat) | Low | High
Heppel et al. 1946a (rabbit) | Moderate | High
Heppel et al. 1948 (dog) | Low | High
Heppel et al. 1948 (rat) | Low | High
Heppel et al. 1948 (mouse) | Low | High
Heppel et al. 1946a (guinea pig) | Low | High
Matsumoto et al. 2013 (mouse) | High | High
Nitschke et al. 1988 (rat) | High | High
Nitschke et al. 1988 (mouse) | High | High
Nitschke et al. 1988 (rabbit) | High | High
Umeda et al. 2010 (rat) | High | High
Inhalation chronic exposure
Human studies
Kumagai et al. 2013, 2014 | Moderate | Moderate
Animal studies
Matsumoto et al. 2013 (mouse) | High | High
Umeda et al. 2010 (rat) | High | High
Oral acute exposure
Human studies
Di Nucci et al. 1988 | Low | Low
Perbellini et al. 1985 | Low | Low
Pozzi et al. 1985 | Low | Low
Animal studies
Berdasco et al. 1988 (rabbit) | High | High
Bruckner et al. 1989 (rat) | Moderate | High
Gi et al. 2015a (rat) | Moderate | High
Gi et al. 2015a (hamster) | Moderate | High
Gorzinski and Johnson 1989 (rat) | High | High
Imberti et al. 1990 (rat) | Low | High
Kirk et al. 1989 (rat) | High | High
Kirk et al. 1995 (rabbit) | High | High
Oral intermediate exposure
Animal studies
Bruckner et al. 1989 (rat) | High | High
Gi et al. 2015a (mouse) | Moderate | High
Gi et al. 2015a (hamster) | High | High
Kirk et al. 1990 (rat) | High | High
NTP 1986 (rat) | Moderate | High
NTP 1986 (mouse) | Moderate | High
Oral chronic exposure
Animal studies
NTP 1986 (rat) | Moderate | Moderate
NTP 1986 (mouse) | Moderate | Moderate
Dermal acute exposure
Human studies
Fiaccadori et al. 2003 | Low | Low
Outcome: Hepatic Effects
Inhalation acute exposure
Human studies
Lucantoni et al. 1991, 1992 | Low | Low
Pozzi et al. 1985 | Low | Low
Animal studies
Di Nucci et al. 1990 (rat) | Low | Moderate
Drew et al. 1978 (rat) | Low | Moderate
Heppel et al. 1946a (rat; 7 hours) | Very Low | Moderate
Heppel et al. 1946a (rat; 5–8 days) | Low | Moderate
Heppel et al. 1946a (mouse; 2–7 hours) | Low | Moderate
Heppel et al. 1946a (rabbit; 2–8 days) | Very Low | Moderate
Heppel et al. 1946a (guinea pig; 5 days) | Low | Moderate
Heppel et al. 1948 (rat) | Moderate | Moderate
Heppel et al. 1948 (mouse) | Moderate | Moderate
Heppel et al. 1948 (guinea pig) | Moderate | Moderate
Highman and Heppel 1946 (rat; 5 days) | Moderate | Moderate
Highman and Heppel 1946 (guinea pig; 7 hours) | Moderate | Moderate
Highman and Heppel 1946 (guinea pig; 2–3 days) | Moderate | Moderate
Nitschke and Johnson 1983 (rat; 6 hours) | Moderate | Moderate
Nitschke and Johnson 1983 (rat; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Moderate | Moderate
Toyooka et al. 2017 | Very Low | Moderate
Wang et al. 2019 (mouse, up to 4 hours) | High | Moderate
Wang et al. 2019 (mouse, 6 hours) | High | Moderate
Zhang et al. 2015 (rat; 7 days) | Low | Moderate
Zhang et al. 2015 (C57BL/6 mouse; 7 days) | Low | Moderate
Zhang et al. 2015 (BALB mouse; 7 days) | Low | Moderate
Zhang et al. 2015 (mouse; 14 days) | Moderate | Moderate
Zhang et al. 2015 (hamster; 7 days) | Low | Moderate
Zhang et al. 2015 (hamster; 14 days) | Moderate | Moderate
Zhang et al. 2015 (guinea pig;7 days) | Low | Moderate
Inhalation intermediate exposure
Animal studies
Heppel et al. 1946a (dog) | Moderate | High
Heppel et al. 1946a (rat) | Moderate | High
Heppel et al. 1946a (rabbit) | Moderate | High
Heppel et al. 1946a (guinea pig) | Moderate | High
Heppel et al. 1948 (dog) | Moderate | High
Heppel et al. 1948 (rat) | Moderate | High
Heppel et al. 1948 (mouse) | Moderate | High
Heppel et al. 1948 (rabbit) | Moderate | High
Matsumoto et al. 2013 (mouse) | High | High
Nitschke et al. 1988 (rat) | High | High
Nitschke et al. 1988 (mouse) | High | High
Nitschke et al. 1988 (rabbit) | High | High
Umeda et al. 2010 (rat) | High | High
Zhang et al. 2018 (mouse) | High | High
Inhalation chronic exposure
Human studies
Kubo et al. 2015 | Low | Low
Animal studies
Matsumoto et al. 2013 (mouse) | High | High
Umeda et al. 2010 (rat) | High | High
Oral acute exposure
Human studies
Chiappino and Secchi 1968 | Low | Low
Di Nucci et al. 1988 | Low | Low
Larcan et al. 1977 | Low | Low
Perbellini et al. 1985 | Low | Low
Pozzi et al. 1985 | Low | Low
Secchi and Alessio 1968 | Low | Low
Thorel et al. 1986 | Low | Low
Animal studies
Berdasco et al. 1988 (rabbit) | Moderate | High
Bruckner et al. 1989 (rat) | High | High
Di Nucci et al. 1988 (rat) | Moderate | High
Gi et al. 2015a (mouse; once) | High | High
Gi et al. 2015a (mouse; 4 days) | High | High
Gi et al. 2015a (hamster; once) | High | High
Gi et al. 2015a (hamster; 4 days) | High | High
Gorzinski and Johnson 1989 (rat) | High | High
Imberti et al. 1990 (rat) | Very Low | High
Kirk et al. 1988 (rabbit) | Moderate | High
Kirk et al. 1989 (rat) | Moderate | High
Kirk et al. 1995 (rat) | Moderate | High
Kirk et al. 1995 (rabbit) | Moderate | High
Oral intermediate exposure
Animal studies
Bruckner et al. 1989 (rat) | High | High
Gi et al. 2015a (mouse) | High | High
Gi et al. 2015a (hamster) | High | High
Kirk et al. 1990 (rat) | High | High
NTP 1986 (rat) | High | High
NTP 1986 (mouse) | High | High
Oral chronic exposure
Animal studies
NTP 1986 (rat) | High | High
NTP 1986 (mouse) | High | High
Dermal acute exposure
Human studies
Fiaccadori et al. 2003 | Low | Low
Outcome: Renal Effects
Inhalation acute exposure
Human studies
Pozzi et al. 1985 | Low | Low
Animal studies
Heppel et al. 1946a (rat; 5–8 days) | Low | Moderate
Heppel et al. 1946a (mouse; 2–7 hours) | Low | Moderate
Heppel et al. 1946a (rabbit; 2–8 days) | Very Low | Moderate
Heppel et al. 1946a (guinea pig; 5 days) | Low | Moderate
Heppel et al. 1948 (rat) | Moderate | Moderate
Heppel et al. 1948 (mouse) | Moderate | Moderate
Heppel et al. 1948 (guinea pig) | Moderate | Moderate
Highman and Heppel 1946 (rat; 5 days) | Moderate | Moderate
Highman and Heppel 1946 (guinea pig; 7 hours) | Moderate | Moderate
Highman and Heppel 1946 (guinea pig; 2–3 days) | Moderate | Moderate
Nitschke and Johnson 1983 (rat; 6 hours) | Moderate | Moderate
Nitschke and Johnson 1983 (rat; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 2 weeks) | Moderate | Moderate
Nitschke and Johnson 1983 (rabbit; 2 weeks) | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
Heppel et al. 1946a (dog) | Moderate | High
Heppel et al. 1946a (rat) | Moderate | High
Heppel et al. 1946a (rabbit) | Moderate | High
Heppel et al. 1946a (guinea pig) | Moderate | High
Heppel et al. 1948 (dog) | Moderate | High
Heppel et al. 1948 (rat) | Moderate | High
Heppel et al. 1948 (mouse) | Moderate | High
Heppel et al. 1948 (guinea pig) | Moderate | High
Matsumoto et al. 2013 (mouse) | High | High
Nitschke et al. 1988 (rat) | High | High
Nitschke et al. 1988 (mouse) | High | High
Nitschke et al. 1988 (rabbit) | High | High
Umeda et al. 2010 (rat) | High | High
Inhalation chronic exposure
Animal studies
Matsumoto et al. 2013 (mouse) | High | High
Umeda et al. 2010 (rat) | High | High
Oral acute exposure
Human studies
Di Nucci et al. 1988 | Low | Low
Perbellini et al. 1985 | Low | Low
Pozzi et al. 1985 | Low | Low
Animal studies
Berdasco et al. 1988 (rabbit) | Moderate | High
Bruckner et al. 1989 (rat) | Moderate | High
Gi et al. 2015a (mouse; 4 days) | High | High
Gi et al. 2015a (hamster; 4 days) | High | High
Gorzinski and Johnson 1989 (rat) | High | High
Imberti et al. 1990 (rat) | Very Low | High
Kirk et al. 1988 (rabbit) | Moderate | High
Kirk et al. 1989 (rat) | Moderate | High
Kirk et al. 1995 (rat) | Moderate | High
Kirk et al. 1995 (rabbit) | Moderate | High
NTP 1986 (rat) | Moderate | High
NTP 1986 (mouse) | Moderate | High
Oral intermediate exposure
Animal studies
Bruckner et al. 1989 (rat) | Moderate | High
Gi et al. 2015a (mouse) | High | High
Gi et al. 2015a (hamster) | High | High
Kirk et al. 1990 (rat) | High | High
NTP 1986 (rat) | High | High
NTP 1986 (mouse) | High | High
Oral chronic exposure
Animal studies
NTP 1986 (rat) | High | High
NTP 1986 (mouse) | High | High
Dermal acute exposure
Human studies
Fiaccadori et al. 2003 | Low | Low
Outcome: CNS Depression
Inhalation acute exposure
Human studies
Kwack et al. 2018 | Low | Low
Rubin 1988 | Low | Low
Animal studies
Heppel et al. 1946a (rat; 7 hours) | Low | Moderate
Heppel et al. 1946a (rat; 5–8 days) | Low | Moderate
Heppel et al. 1946a (mouse; 2–7 hours) | Low | Moderate
Heppel et al. 1946a (guinea pig; 5 days) | Low | Moderate
Nitschke and Johnson 1983 (rat; 6 hours) | Moderate | Moderate
Nitschke and Johnson 1983 (mouse; 6 hours) | Moderate | Moderate
Sidorenko et al. 1976 (mouse) | Very low | Moderate
Sidorenko et al. 1979 (rat) | Very low | Moderate
Inhalation intermediate exposure
Animal studies
Sidorenko et al. 1979 (rat) | Very low | Very Low
Oral acute exposure
Human studies
Larcan et al. 1977 | Low | Low
Perbellini et al. 1985 | Low | Low
Animal studies
Bruckner et al. 1989 (rat) | Moderate | High
Exxon 1981a (rat) | Low | High
Gorzinski and Johnson 1989 (rat) | High | High
Kirk et al. 1988 (rabbit) | Moderate | High
Kirk et al. 1989 (rat) | High | High
Kirk et al. 1995 (rat) | Moderate | High
Kirk et al. 1995 (rabbit) | Moderate | High
Shell Oil Co. 1982 (rat) | Moderate | High
Oral intermediate exposure
Animal studies
Bruckner et al. 1989 (rat) | Moderate | High
Johnson and Gorzinski 1988 (rat) | High | High
Outcome: Developmental Effects
Oral acute exposure
Animal studies
Kirk et al. 1995 (rat) | High | High
Kirk et al. 1995 (rabbit) | High | High
Oral intermediate exposure
Animal studies
Kirk et al. 1990 (rat) | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for upper respiratory, hematological, hepatic, renal, CNS depression, and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with 1,2-dichloropropane exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Upper Respiratory Effects
Human studies | Low | -2 risk of bias | Very Low
Animal studies | High | +1 consistency in findings; +1 large magnitude of effect | High
Outcome: Hematological Effects
Human studies | Low | -2 risk of bias, +1 consistency in findings | Very Low
Animal studies | High | None | High
Outcome: Hepatic Effects
Human studies | Low | -2 risk of bias, +1 consistency in findings | Very Low
Animal studies | High | +1 consistency in findings | High
Outcome: Renal Effects
Human studies | Low | -2 risk of bias | Very Low
Animal studies | High | -2 inconsistency | Low
Outcome: CNS Depression
Human studies | Low | -2 risk of bias | Very Low
Animal studies | High | +1 consistency in findings | High
Outcome: Developmental Effects
Animals studies | High | None | High

Table C-17 Confidence in the Body of Evidence for 1,2-Dichloropropane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Upper respiratory effects | Very Low | High
Hematological effects | Very Low | High
Hepatic effects | Very Low | High
Renal effects | Very Low | Low
CNS depression | Very Low | High
Developmental effects | No data | High

- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for 1,2-dichloropropane, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for 1,2-dichloropropane is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for 1,2-Dichloropropane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Upper respiratory effects | Very Low | Heath effect | Inadequate
Hematological effects | Very Low | Health effect | Inadequate
Hepatic effects | Very Low | Health effect | Inadequate
Renal effects | Very Low | Health effect | Inadequate
CNS depression | Very Low | Health effect | Inadequate
Developmental effects | No data | No data | Inadequate
Animal studies
Upper respiratory effects | High | Health effect | High
Hematological effects | High | Health effect | High
Hepatic effects | High | Health effect | High
Renal effects | Low | Mixed | Low
CNS depression | High | Health effect | High
Developmental effects | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below.

Figure C-1 Hazard Identification Scheme

Figure C-1 description

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for 1,2-dichloropropane are listed below and summarized in Table C-19.

Table C-19 Hazard Identification Conclusions for 1,2-Dichloropropane

Outcome | Hazard identification
Upper respiratory effects following inhalation exposure | Presumed health effect
Hematological effects | Presumed health effect
Hepatic effects | Presumed health effect
Renal effects | Not classifiable
CNS depression | Presumed health effect
Developmental effects | Presumed health effect

Presumed Health Effects

- Upper respiratory effects
  ○ Inadequate evidence from case reports of respiratory irritation following accidental industrial spills (Rubin 1988; ACGIH 2014)
  ○ High level of evidence of nasal lesions in rats, mice, and rabbits following intermediate or chronic inhalation exposure (Matsumoto et al. 2013; Nitschke et al. 1988; Umeda et al. 2010).
- Hematological effects
  ○ Although several case studies report hemolytic anemia and/or disseminating intravascular coagulation following acute inhalation, oral, or dermal exposure to 1,2-dichloropropane at unknown exposure levels (Di Nucci et al. 1988; Fiaccadori et al. 2003; Lucantoni et al. 1991, 1992; Perbellini et al. 1985; Pozzi et al. 1985), the human data were considered inadequate for evaluating the potential hazard due to the low initial confidence in these studies and the high risk of bias.
  ○ High level of evidence for hemolytic anemia in laboratory animals following inhalation or oral exposure (Berdasco et al. 1988; Bruckner et al. 1989; Imberti et al. 1990; Kirk et al. 1990, 1995; Matsumoto et al. 2013; Nitschke et al. 1988; Umeda et al. 2010).
- Hepatic effects
  ○ Although a number of case reports indicate that the liver is a target of toxicity following inhalation, oral, or dermal exposure to 1,2-dichloropropane at unknown exposure levels (Chiappino and Secchi 1968; Di Nucci et al. 1988; Fiaccadori et al. 2003; Larcan et al. 1977; Lucantoni et al. 1991, 1992; Kubo et al. 2015; Perbellini et al. 1985; Pozzi et al. 1985; Secchi and Alessio 1968; Thorel et al. 1986), the human data were considered inadequate for evaluating the potential hazard due to the low initial confidence in these studies and the high risk of bias.
  ○ High level of evidence of hepatic toxicity in laboratory animals following inhalation or oral exposure (Bruckner et al. 1989; Heppel et al. 1946a, 1948; Highman and Heppel 1946; Gorzinski and Johnson 1989; Gi et al. 2015a; Kirk et al. 1990; Matsumoto et al. 2013; NTP 1986; Umeda et al. 2010; Zhang et al. 2015).
- CNS depression
  ○ Although several case studies report severe CNS depression following acute inhalation or oral exposure to 1,2-dichloropropane at unknown exposure levels (Larcan et al. 1977; Perbellini et al. 1985; see also reviews by ACGIH 2014; EPA 2016a; IARC 2017), the human data were considered inadequate for evaluating the potential hazard due to the low initial confidence in these studies and the high risk of bias.
  ○ High level of evidence from acute oral studies in laboratory animals (Bruckner et al. 1989; Exxon 1981a; Gorzinski and Johnson 1989; Kirk et al. 1989; Shell Oil Co. 1982) and low level of evidence from acute inhalation studies (Heppel et al. 1946a).
- Developmental effects
  ○ No data are available on whether inhalation, oral, or dermal exposure to 1,2-dichloropropane alters human development.
  ○ High level evidence in oral animal studies based on delayed ossification following gestational exposure in rats and rabbits and decreased neonatal survival and body weight in a 2-generation study in rats at doses associated with maternal toxicity (Kirk et al. 1990, 1995). No data are available on whether inhalation exposure to 1,2-dichloropropane alters animal development.

Not Classifiable Effects

- Renal effects
  ○ A few case reports indicate that the kidney is a target of toxicity following inhalation or oral exposure to 1,2-dichloropropane at unknown exposure levels (Di Nucci et al. 1988; Perbellini et al. 1985; Pozzi et al. 1985); however, the human data were considered inadequate for evaluating the potential hazard due to the low initial confidence in these studies and the high risk of bias.
  ○ Low evidence of renal toxicity in laboratory animals due to inconsistent evidence in inhalation studies (Heppel et al. 1946a, 1948; Highman and Heppel 1946; Matsumoto et al. 2013) and lack of evidence in oral studies (Bruckner et al. 1989; Gi et al. 2015a; Gorzinski and Johnson 1989; Kirk et al. 1990; NTP 1986).