# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL | 0.02 ppm
Critical Effect: | Nasal lesions
Reference: | Nitschke and Johnson 1983
Point of Departure: | 100 ppm minimal LOAEL (LOAEL_HEC_ of 1.8 ppm)
Uncertainty Factor: | 90
LSE Graph Key: | 9
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.02 ppm was derived for 1,2-dichloropropane based on olfactory mucosal degeneration in rats exposed to concentrations ≥100 ppm for 2 weeks (6 hours/day, 4–5 days/week); a no-observed-adverse-effect level (NOAEL) was not identified for nasal effects (Nitschke and Johnson 1983). The MRL is based on the lowest-observed-adverse-effect level (LOAEL) of 100 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (LOAEL_HEC_) of 1.8 ppm for slight olfactory mucosal degeneration and a total uncertainty factor of 90 (3 for use of a minimal LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: Available data indicate that the upper respiratory system is the most sensitive target for toxic effects following acute-duration inhalation exposure to 1,2-dichloropropane (see Table A-1). Hepatic effects were also considered, but these effects occurred at concentrations 2–4-fold higher than the lowest LOAEL identified for nasal lesions. Of the species evaluated for nasal lesions, the rat was the most sensitive, with a LOAEL of 100 ppm for degeneration of the nasal mucosa (lowest concentrations tested). The LOAEL values for nasal lesions in other species evaluated in this study were higher than the rat LOAEL (300 ppm for mice, 1,000 ppm for rabbits); therefore, the rat is considered the most sensitive species for the critical effect.

Table A-1 Summary of Candidate Critical Effects for Acute Inhalation MRL for 1,2-Dichloropropane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Nasal effects
Fischer-344 rat | 2 weeks (4–5 days/week; 6 hours/day) | ND | 100 | Olfactory mucosal degeneration | Nitschke and Johnson 1983
B6C3F1 mouse | 2 weeks (4–5 days/week; 6 hours/day) | 100 | 300 | Olfactory mucosal degeneration | Nitschke and Johnson 1983
New Zealand rabbit | 2 weeks (4–5 days/week; 6 hours/day) | 300 | 1,000 | Olfactory mucosal degeneration | Nitschke and Johnson 1983
Hepatic effects
BALB/cA mouse | 14 days (6 hours/day) | ND | 200 | Hepatic vacuolation | Zhang et al. 2015
BALB/cA mouse | 7 days (8 hours/day) | ND | 300 | Hepatic vacuolation | Zhang et al. 2015
C57BL/6J mouse | 7 days (8 hours/day) | ND | 300 | Hepatic vacuolation | Zhang et al. 2015
C57BL/6J mice | 1–12 days (7 hours/day) | ND | 400 | Slight fatty degeneration | Heppel et al. 1948
Golden Syrian hamster | 14 days (8 hours/day) | 200 | 400 | Slight dilation of hepatic sinusoids | Zhang et al. 2015
Golden Syrian hamster | 7 days (8 hours/day) | 300 | ND | ND | Zhang et al. 2015

LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The study with the lowest identified LOAEL for the critical effect of nasal lesions was selected as the principal study (Nitschke and Johnson 1983). Of the species tested in this study, the rat was the most sensitive, with a LOAEL of 100 ppm for degeneration of the nasal mucosa (lowest concentrations tested). The LOAEL values for nasal lesions in other species evaluated in this study were 300 ppm for mice and 1,000 ppm for rabbits.

Summary of the Principal Study:

Nitschke KD, Johnson KA. 1983. Propylene dichloride: One day and two week inhalation toxicity in rats. Dow Chemical Company, Midland, MI.

Groups of F344 rats (5/sex) were exposed to 1,2-dichloropropane at concentrations of 0, 100, 300, or 1,000 ppm for 6 hours/day for 9 days over a 2-week period. Animals were observed for signs of toxicity after each exposure period. Body weights were recorded prior to the 1st, 5th, 6th, and 9th exposure. Prior to the 9th exposure, blood was collected for hematology and clinical chemistry. Urine was collected for urinalysis. All surviving animals were sacrificed the day following the final exposure. All animals were examined grossly. The brain, heart, liver, kidneys, thymus, and testes were removed and weighed. The entire respiratory tract (nasal turbinates, larynx, trachea, and lungs), adrenals, liver, kidney, testes, thymus, and bone marrow were examined for histopathological changes.

No deaths or clinical signs of toxicity were observed during the exposure period. All treated rats had significantly reduced body weight gain, which was attributed to reduced food intake by the study authors. No exposure-related hematological effects were observed. Blood chemistry findings were consistent with decreased food intake, and not considered by the study authors to be related to toxicity. Female rats had decreased plasma cholinesterase activities that were not dose related. No effects on urinalysis indices were observed. Relative liver weight was significantly increased by 8–15% in male rats at 1,000 ppm and female rats at 300 and 1,000 ppm; these findings may be exposure related. Other observed organ weight changes were considered secondary to decreased food intake. Olfactory mucosal degeneration was observed in 100% of rats from all exposure groups, and none of the control rats. The severity of this lesion increased in a dose-related manner, from slight at 100 ppm to severe at 1,000 ppm. Inflammatory and exudative changes were also increased in a dose-related manner in the nasal tissue. No other respiratory tract lesions were observed. Decreased cellularity of bone marrow and thymus observed at 300 and 1,000 ppm is consistent with stress as a result of decreased food intake. The bone marrow changes did not correlate with hematological parameters. Slight hepatocellular hypertrophy in 3/5 female rats exposed to 1,000 ppm is consistent with increased liver weight. No exposure-related histopathologic lesions were observed in kidneys, adrenals, or testes.

Selection of the Point of Departure for the MRL: The LOAEL of 100 ppm for nasal lesions was selected as the POD. This value was considered a minimal LOAEL due to the slight severity of the lesion. The data were not suitable for benchmark dose (BMD) modeling because incidence data went from 0% in the control to 100% in the lowest concentration group.

Adjustment for Intermittent Exposure: The LOAEL was adjusted from intermittent exposure to account for a continuous exposure scenario:

- LOAEL_ADJ_ = 100 ppm × (6 hours/24 hours) × (9 days/14 days) = 16 ppm

Human Equivalent Concentration: A human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted LOAEL by the regional gas dose ratio (RGDR) for the extrathoracic region of the respiratory tract. The RGDR_ET_ of 0.115 was calculated using the following equation:

- RGDR_ET_ = (V_E_/SA_ET_)_A_/(V_E_/SA_ET_)_H_

where:

- ET = extrathoracic region
- V_E_ = minute volume (mL/minute)
- SA = surface area (cm^2^)
- A = animal (rat)
- H = human

- V_E_ = 119 mL/minute and SA_ET_ = 15 cm^2^ in rats and V_E_ = 13,800 mL/minute and SA_ET_ = 200 cm^2^ in humans (EPA 1994).
  - RGDR_ET_ = (119 mL/minute ÷ 15 cm^2^)/(13,800 mL/minute ÷ 200 cm^2^) = 0.115
  - LOAEL_HEC_ = LOAEL_ADJ_ × RGDR_ET_
  - LOAEL_HEC_ = 16 ppm × 0.115= 1.8 ppm

Uncertainty Factor: The LOAEL_HEC_ is divided by a total uncertainty factor of 90:

- 3 for use of a minimal LOAEL. The dose was considered a minimal LOAEL because the severity of the lesions was graded as slight.
- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

- MRL = LOAEL_HEC_ ÷ UFs
- MRL = 1.8 ppm ÷ (3 × 3 × 10) = 0.02 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The upper respiratory tract is the most sensitive target following both acute- and intermediate-duration inhalation exposure, and the rat is the most sensitive species tested. Olfactory mucosal degeneration was observed in rats and mice exposed to ≥100 ppm and rabbits at 1,000 ppm for 2 weeks (Nitschke and Johnson 1983). In intermediate-duration studies, nasal cavity lesions were observed in rats exposed to ≥15 ppm (lowest concentration tested), including hyperplasia of the respiratory epithelium at ≥15 ppm, degeneration of the olfactory epithelium at ≥50 ppm, atrophy of the olfactory epithelium at ≥125 ppm, submucosal inflammation at ≥150 ppm, and inflammation of the respiratory epithelium at ≥1,000 ppm (Nitschke et al. 1988; Umeda et al. 2010). Intermediate-duration studies also observed nasal lesions in mice at ≥300 ppm (but not ≤200 ppm) (Matsumoto et al. 2013; Nitschke et al. 1988) and rabbits at 1,000 ppm (but not ≤500 ppm) (Nitschke et al. 1988). In chronic studies, nasal lesions were observed in rats at ≥80 ppm (lowest concentration tested), including atrophy of olfactory epithelium, inflammation of the respiratory epithelium, squamous cell metaplasia of respiratory epithelium, hyperplasia of the transitional epithelium, squamous cell hyperplasia, and hyperplasia of the submucosal glands (Umeda et al. 2010) and mice at ≥80 ppm (but not 32 ppm), including atrophy of olfactory epithelium and metaplasia of the olfactory epithelium and submucosal glands (Matsumoto et al. 2013).

Limited evidence from accident reports following chemical spills suggest that inhalation exposure to 1,2-dichloropropane causes respiratory irritation in humans following acute exposure to presumably high concentrations (exposure levels not available) (ACGIH 2014; Rubin 1988).

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL | 0.002 ppm
Critical Effect: | Nasal lesions
Reference: | Nitschke et al. 1988
Point of Departure: | BMCL_10_ of 2.38 (BMCL_HEC_ of 0.05 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 35
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.002 ppm was derived for 1,2-dichloropropane based on hyperplasia of the nasal respiratory epithelium in rats exposed to concentrations ≥15 ppm for 13 weeks (6 hours/day, 5 days/week); a NOAEL was not identified for nasal effects (Nitschke et al. 1988). The MRL is based on the BMCL_10_ of 2.38 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_HEC_) of 0.05 ppm for hyperplastic lesions in male and female rats (combined) and a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available data indicate that the upper respiratory system is the most sensitive target for toxic effects following intermediate-duration inhalation exposure to 1,2-dichloropropane (see Table A-2). Other effects considered (hemolytic anemia, altered estrous cycle) occurred at concentrations 6–10-fold higher than the lowest LOAEL identified for nasal lesions; no NOAEL was identified for nasal lesions.

Table A-2 Summary of Candidate Critical Effects for Intermediate Inhalation MRL for 1,2-Dichloropropane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Respiratory effects^a^
F344 rat | 13 weeks (6 hours/day, 5 days/week) | ND | 15 | Hyperplasia of nasal respiratory epithelium | Nitschke et al. 1988
F344 rat | 13 weeks (6 hours/day, 5 days/week) | ND | 125 | Hyperplasia of nasal respiratory epithelium and atrophy of olfactory epithelium | Umeda et al. 2010
B6D2F1/Crlj mouse | 13 weeks (6 hours/day, 5 days/week) | 200 | 300 | Respiratory metaplasia, atrophy, necrosis, and desquamation of nasal cavity | Matsumoto et al. 2013
Reproductive effects
F344 rat | 21–24 days (8 hours/day) | 50 | 100 | Lengthened estrous cycle | Sekiguchi et al. 2002
Hematological effects
New Zealand rabbit | 13 weeks (6 hours/day, 5 days/week) | ND | 150 | Hemolytic anemia | Nitschke et al. 1988

a Selected critical effect.

LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The study with the lowest identified LOAEL for the critical effect of nasal lesions was selected as the principal study (Nitschke et al. 1988).

Summary of the Principal Study:

Nitschke KD, Johnson KA, Wackerle DL, . 1988. Final report on propylene dichloride 13-week inhalation toxicity study with rats, mice and rabbits with cover letter dated 032888. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000399-1. FYI-OTS-0488-0399.

Groups of F344 rats (10/sex/group) were exposed to 1,2-dichloropropane (99.94% pure) via whole-body inhalation for 13 weeks (5 days/week, 6 hours/day) at concentrations of 0, 15, 50, or 150 ppm. Endpoints examined included mortality, clinical signs, weekly body weight, eyes (fluorescent illumination), hematology, clinical chemistry, organ weights (brain, heart, liver, kidneys, thymus, testes), and histology for complete set of 47 tissues including the respiratory tract (nasal tissues, larynx, trachea, lungs, and organs normally present on sections with these organs) in control and high-exposure groups. The respiratory tract, liver, gallbladder, kidney, and thymus were also examined in the low- and mid-exposure groups.

There were no exposure-related mortalities or overt signs of toxicity. Body weight gain was significantly lower than controls throughout the study in rats exposed to 150 ppm, but body weight decreases >10% were only observed in males. There were no exposure-related effects on hematological, clinical chemistry, or urinalysis parameters or on organ weights. Hyperplasia of nasal mucosa was observed in 0/10, 2/9, 5/10, and 9/10 males and 0/10, 3/10, 7/10, and 9/10 females at 0, 15, 50, and 150 ppm, respectively. Slight degeneration of olfactory mucosa was observed in rats exposed to 50 and 150 ppm, with inflammation of larynx in males exposed to 150 ppm. No other exposure-related histopathologic lesions were observed. The authors considered hyperplasic lesions of nasal mucosa to be protective response of equivocal toxicological significance; ATSDR generally considers hyperplasic lesions to be an adverse effect. Furthermore, additional nasal lesions are observed at higher concentrations and following longer exposure durations (see Umeda et al. 2010). Therefore, the lowest concentration (15 ppm) was identified as a LOAEL for upper respiratory lesions; no NOAEL was identified.

Selection of the Point of Departure for the MRL: The BMCL_10_ value of 2.38 ppm for increased incidence of nasal respiratory epithelium hyperplasia in male and female rats (combined) was selected as the basis of the MRL.

BMD modeling was performed on the incidence of nasal respiratory epithelium hyperplasia in male and female F344 rats, as well as the combined data for both sexes (Table A-3). The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2) using a benchmark response (BMR) of 10% extra risk. However, dichotomous Hill models were not considered viable because the model has four parameters, requiring at minimum five data points (including control), and these data sets have only four data points. For remaining models, adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMCL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the benchmark concentration) was selected as the POD when the difference between the BMCLs estimated from these models was ≥3-fold; otherwise, the BMCL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

Table A-3 Incidence of Nasal Respiratory Epithelium Hyperplasia in F344 Rats Following Inhalation Exposure to 1,3-Dichloropropane for 13 Weeks

| Concentration (ppm)
| 0 | 15 | 50 | 150
Males | 0/10 (0%) | 2/9 (22%) | 5/10 (50%) | 9/10 (90%)
Females | 0/10 (0%) | 3/10 (30%) | 7/10 (70%) | 9/10 (90%)
Combined | 0/20 (0%) | 5/19 (25%) | 12/20 (60%) | 18/20 (90%)

Source: Nitschke et al. 1988

All models except dichotomous Hill provided adequate fit to the increased incidence of nasal lesions in male rats. BMCLs for models providing adequate fit were not sufficiently close (differed by ≥3-fold), so the model with the lowest BMCL was selected (Log-Logistic). The frequentist, restricted Log-Logistic model estimated a BMC_10_ and BMCL_10_ of 9.08 and 2.44 ppm, respectively. The results of the BMD modeling are summarized in Table A-4.

Table A-4 Model Predictions for Incidence of Nasal Respiratory Epithelium Hyperplasia in Male F344 Rats Exposed to 1,2-Dichloropropane for 13 Weeks (Nitschke et al. 1988)

Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMC | Dose near control
Dichotomous Hill | | | 0.55 | 36.27 | 0.273 | -3.90x10^-4^
Gamma^d^ | 7.05 | 4.54 | 1.00 | 31.96 | -3.90x10^-4^ | -3.90x10^-4^
Log-Logistic ^e^ ^,^ ^f^ | 9.08 | 2.44 | 0.83 | 34.27 | 0.273 | -3.90x10^-4^
Log-Probit^e^ | 11.59 | 7.44 | 0.76 | 34.41 | 0.577 | -3.90x10^-4^
Multistage (3-degree)^g^ | 7.21 | 4.54 | 0.97 | 33.95 | -3.90x10^-4^ | -3.90x10^-4^
Multistage (2-degree)^g^ | 7.17 | 4.54 | 0.97 | 33.95 | -3.90x10^-4^ | -3.90x10^-4^
Multistage (1-degree)^g^ | 7.05 | 4.54 | 1.00 | 31.96 | -3.90x10^-4^ | -3.90x10^-4^
Weibull^d^ | 7.05 | 4.54 | 0.97 | 33.96 | -3.94x10-4 | -3.94x10^-4^
Logistic | 21.20 | 13.30 | 0.32 | 37.21 | 0.399 | -1.13
Probit | 20.89 | 13.84 | 0.32 | 37.19 | 0.422 | -1.11

a BMC and BMCL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Selected model. All models except the dichotomous Hill model provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by ≥3-fold), so the model with the lowest BMCL was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

For increased incidence of nasal lesions in female rats, six frequentist, restricted models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Multistage 1-, 2-, and 3-degree). The Multistage models, which all converged on the 1-degree model, estimated a BMC_10_ and BMCL_10_ of 5.28 and 3.45 ppm, respectively. The results of the BMD modeling are summarized in Table A-5.

Table A-5 Model Predictions for Incidence of Nasal Respiratory Epithelium Hyperplasia in Female F344 Rats Exposed to 1,2-Dichloropropane for 13 Weeks (Nitschke et al. 1988)

Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMC | Dose near control
Dichotomous Hill | | | NA | 38.94 | -4.04x10^-4^ | -4.04x10^-4^
Gamma^d^ | 5.28 | 3.45 | 0.67 | 35.64 | -3.92x10^-4^ | -3.92x10^-4^
Log-Logistic^e^ | | | 0.99 | 34.95 | -3.90x10^-4^ | -3.90x10^-4^
Log-Probit^e^ | 8.31 | 5.32 | 0.74 | 35.44 | 0.405 | -3.90x10^-4^
Multistage (3-degree)^f^ | 5.28 | 3.45 | 0.85 | 33.64 | -3.90x10^-4^ | -3.90x10^-4^
Multistage (2-degree)^f^ | 5.28 | 3.45 | 0.85 | 33.64 | -3.90x10^-4^ | -3.90x10^-4^
Multistage (1-degree) ^f^ ^,^ ^g^ | 5.28 | 3.45 | 0.85 | 33.64 | -3.90x10^-4^ | -3.90x10^-4^
Weibull^d^ | 5.28 | 3.45 | 0.67 | 35.64 | -8.25x10^-3^ | -8.25x10^-3^
Logistic | | | 0.09 | 41.09 | 0.366 | -0.142
Probit | | | 0.08 | 41.47 | 0.361 | -0.145

a BMC and BMCL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. All models except the LogLogistic, Logistic, Probit, and dichotomous Hill models provided adequate fit to the data (the Weibull and 2- and 3-degree Multistage 2- and 3-degree models converged onto the 1-degree Multistage model). BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (1-Degree Multistage).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

For nasal lesions in male and female rats (combined), seven frequentist, restricted models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by 3-fold), so the lowest BMCL was selected (Log-Logistic). The Log-Logistic model estimated a BMC_10_ and BMCL_10_ of 6.78 and 2.38 ppm, respectively. The results of the BMD modeling are summarized in Table A-6.

Table A-6 Model Predictions for Incidence of Nasal Respiratory Epithelium Hyperplasia in Male and Female F344 Rats exposed to 1,2-Dichloropropane for 13 Weeks (Nitschke et al. 1988)

Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (mg/kg/day) | BMCL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMC | Dose near control
Dichotomous Hill | | | 0.70 | 67.98 | -5.52x10^-4^ | -5.52x10^-4^
Gamma^d^ | 6.10 | 4.48 | 0.84 | 66.16 | -5.57x10^-4^ | -5.57x10^-4^
Log-Logistic ^e^ ^,^ ^f^ | 6.76 | 2.38 | 0.70 | 67.98 | -5.52x10^-4^ | -5.52x10^-4^
Log-Probit^e^ | 9.80 | 7.17 | 0.84 | 64.62 | 0.737 | -5.52x10^-4^
Multistage (3-degree)^g^ | 6.10 | 4.48 | 0.95 | 64.16 | -5.52x10^-4^ | -5.52x10^-4^
Multistage (2-degree)^g^ | 6.10 | 4.48 | 0.95 | 64.16 | -5.52x10^-4^ | -5.52x10^-4^
Multistage (1-degree)^g^ | 6.10 | 4.48 | 0.84 | 66.16 | -5.52x10^-4^ | -5.52x10^-4^
Weibull^d^ | 6.10 | 4.48 | 0.95 | 64.16 | -5.52x10^-4^ | -5.52x10^-4^
Logistic | | | 0.04 | 74.98 | 0.550 | -1.82
Probit | | | 0.03 | 75.27 | 0.565 | -1.82

a BMC and BMCL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Selected model. All models except the Logistic, Probit, and dichotomous Hill models provided adequate fit to the data. BMCLs for remaining models providing adequate fit were not sufficiently close (differed by ≥3-fold), so the model with the lowest BMCL was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Table A-7 summarizes the potential candidate PODs for the intermediate-duration inhalation MRL for 1,2-dichloropropane. While the female data have the lowest BMC, the BMCL of 2.38 ppm from the combined male and female data was selected as the POD for the MRL derivation because it has the highest statistical power. The Log-Logistic model fit to the nasal respiratory epithelium hyperplasia in the male and female rats presented in Figure A-1.

Table A-7 Candidate Points of Departure 1,2-Dichloropropane Intermediate-Duration Inhalation MRL

Endpoint | BMC_10_ (ppm) | BMCL_10_ (ppm)
Increased incidence of nasal lesions in males | 9.08 | 2.44
Increased incidence of nasal lesions in females | 5.28 | 3.45
Increased incidence of nasal lesions in males and females (combined) | 6.76 | 2.38

BMC = benchmark concentration; BMCL = 95% lower confidence limit on the BMC; MRL = Minimal Risk Level

Figure A-1 Fit of Log-Logistic Model to Data for Combined Incidence of Nasal Respiratory Epithelium Hyperplasia in Male and Female F344 Rats Exposed to 1,2-Dichloropropane for 13 Weeks

Figure A-1 description

Adjustment for Intermittent Exposure: The BMCL_10_ of 2.38 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

- BMCL_ADJ_ = 2.38 ppm × (6 hours/24 hours) × (5 days/7 days) = 0.43 ppm

Human Equivalent Concentration: A human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted BMCL by the regional gas dose ratio (RGDR) for the extrathoracic region of the respiratory tract. The RGDR_ET_ of 0.115 was calculated using the following equation:

- RGDR_ET_ = (V_E_/SA_ET_)_A_/(V_E_/SA_ET_)_H_

where:

- ET = extrathoracic region
- V_E_ = minute volume (mL/minute)
- SA = surface area (cm^2^)
- A = animal (rat)
- H = human

- V_E_ = 119 mL/minute and SA_ET_ = 15 cm^2^ in rats and V_E_ = 13,800 mL/minute and SA_ET_ = 200 cm^2^ in humans (EPA 1994).

- RGDR_ET_ = (119 mL/minute ÷ 15 cm^2^)/(13,800 mL/minute ÷ 200 cm^2^) = 0.115
  - BMCL_HEC_ = BMCL_ADJ_ × RGDR_ET_
  - BMCL_HEC_ = 0.43 ppm × 0.115 = 0.05 ppm

Uncertainty Factor: The BMCL_10[HEC]_ is divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

- MRL = BMCL_10[HEC]_ ÷ UFs
- MRL = 0.05 ppm ÷ (3 × 10) = 0.002 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The upper respiratory tract is the most sensitive target following both acute- and intermediate-duration inhalation exposure, and the rat is the most sensitive species tested. As discussed in the acute-duration inhalation MRL worksheet, olfactory mucosal degeneration was observed in rats and mice exposed to ≥100 ppm and rabbits at 1,000 ppm for 2 weeks (Nitschke and Johnson 1983). In intermediate-duration studies, nasal cavity lesions were observed in rats exposed to ≥15 ppm (lowest concentration tested), including hyperplasia of the respiratory epithelium at ≥15 ppm, degeneration of the olfactory epithelium at ≥50 ppm, atrophy of the olfactory epithelium at ≥125 ppm, submucosal inflammation at ≥150 ppm, and inflammation of the respiratory epithelium at ≥1,000 ppm (Nitschke et al. 1988; Umeda et al. 2010). Intermediate-duration studies also observed nasal lesions in mice at ≥300 ppm (but not ≤200 ppm) (Matsumoto et al. 2013; Nitschke et al. 1988) and rabbits at 1,000 ppm (but not ≤500 ppm) (Nitschke et al. 1988). In chronic studies, nasal lesions were observed in rats at ≥80 ppm (lowest concentration tested), including atrophy of olfactory epithelium, inflammation of the respiratory epithelium, squamous cell metaplasia of respiratory epithelium, hyperplasia of the transitional epithelium, squamous cell hyperplasia, and hyperplasia of the submucosal glands (Umeda et al. 2010) and mice at ≥80 ppm (but not 32 ppm), including atrophy of olfactory epithelium and metaplasia of the olfactory epithelium and submucosal glands (Matsumoto et al. 2013).

Limited evidence from accident reports following chemical spills suggest that inhalation exposure to 1,2-dichloropropane causes respiratory irritation in humans following acute exposure to presumably high concentrations (exposure levels not available) (ACGIH 2014; Rubin 1988).

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: A chronic-duration inhalation MRL was not derived due to lack of adequate low-concentration data for the critical effect. As a result, there is too much uncertainty in the chronic database to support derivation of an MRL based on chronic data. It is not considered appropriate to use the intermediate-duration data for derivation of a chronic MRL because there is evidence that the severity of nasal lesions increases with longer durations of exposure. Therefore, we cannot be sure that the intermediate MRL would be protective for chronic exposure. Two chronic-duration inhalation studies evaluating comprehensive endpoints in rats and mice are available (Matsumoto et al. 2013; Umeda et al. 2010); the results of these studies are summarized in Table A-8. The most sensitive effect identified in rats was nasal lesions at ≥80 ppm (lowest concentration tested); the lesions included atrophy of the olfactory epithelium, inflammation and squamous cell metaplasia of respiratory epithelium, and hyperplasia of the transitional epithelium (Umeda et al. 2010). In mice, the most sensitive effect was basophilic changes and cortical mineralization in the kidney of male mice at ≥32 ppm (lowest concentration tested) and atrophy of the olfactory epithelium at ≥80 ppm (Matsumoto et al. 2013). While the LOAEL identified for renal effects was lower than the LOAEL identified for nasal lesions, renal effects were not selected as critical effects because there is a lack of consistent evidence for renal effects in exposed animals and the systematic review of renal toxicity determined that data are inadequate to determine if kidney toxicity will be observed in humans exposed to 1,2-dichloropropane. Therefore, the lowest LOAEL for the critical effect of nasal lesions was 80 ppm. This LOAEL is >5-fold higher than the LOAEL observed for nasal lesions following intermediate-duration exposure (15 ppm; Nitschke et al. 1988). Therefore, available chronic studies are inadequate to characterize low-concentration effects of chronic 1,2-dichloropropane inhalation exposure.

Table A-8 Summary of Candidate Critical Effects for Chronic Inhalation MRL for 1,2-Dichloropropane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Respiratory effects
F344 rat | 104 weeks (6 hours/day, 5 days/week) | ND | 80 | Atrophy of olfactory epithelium, inflammation and squamous cell metaplasia of respiratory epithelium, and hyperplasia of the transitional epithelium | Umeda et al. 2010
B6D2F1/Crlj mouse | 104 weeks (6 hours/day, 5 days/week) | 32 | 80 | Atrophy of olfactory epithelium | Matsumoto et al. 2013
Renal effects
B6D2F1/Crlj mouse | 104 weeks (6 hours/day, 5 days/week) | ND | 32 | Basophilic changes and cortical mineralization in kidney; males only | Matsumoto et al. 2013

LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.3 mg/kg/day
Critical Effect: | Maternal anemia
Reference: | Berdasco et al. 1988 and Kirk et al. 1995
Point of Departure: | BMDL_1SD_ of 30 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 17, 18
Species: | Rabbit

MRL Summary: An acute-duration oral MRL of 0.3 mg/kg/day was derived for 1,2-dichloropropane based on evidence of maternal anemia in rabbits exposed to doses ≥100 mg/kg/day on gestation days 7–19 (Berdasco et al. 1988; Kirk et al. 1995). The MRL is based on the BMDL_1SD_ of 30 mg/kg/day for increased maternal reticulocyte counts relative to control animals and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Several studies have evaluated the toxicity of 1,2-dichloropropane following acute-duration oral exposure. The most sensitive effects identified in acute oral studies included hematological, developmental, neurological, and body weight effects; see Table A-9. Since all of these adverse effects occurred at similar doses, all were considered for MRL derivation.

Table A-9 Summary of Candidate Critical Effects for Acute Oral MRL for 1,2-Dichloropropane

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hematological effects
New Zealand rabbit | GDs 7–19 (GO) | 25 | 100 | Maternal anemia | Berdasco et al. 1988
New Zealand rabbit | GDs 7–19 (GO) | 50 | 150 | Maternal anemia | Kirk et al. 1995
Developmental effects
Sprague-Dawley rat | GDs 6–15 (GO) | 30 | 125 | Delayed skull ossification | Kirk et al. 1995
New Zealand rabbit | GDs 7–19 (GO) | 50 | 150 | Delayed skull ossification | Kirk et al. 1995
Neurological effects
Sprague-Dawley rat | 1–10 days (GO) | ND | 100 | CNS depression | Bruckner et al. 1989
Sprague-Dawley rat | GDs 6–15 (GO) | 30 | 125 | Clinical signs of neurotoxicity in dams | Kirk et al. 1995
Wistar rat | Once (G) | ND | 145 | CNS depression | Shell Oil Co. 1982
Body weight effects
Sprague-Dawley rat | GDs 6–15 (GO) | 30 | 125 | Decreased maternal body weight gain | Kirk et al. 1995

CNS = central nervous system; G = gavage (no vehicle); GD = gestation day; GO = gavage (oil vehicle); LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; ND = not determined

In order to identify the most sensitive endpoint, BMD modeling was attempted for candidate critical endpoints in Table A-9 when data were amenable to modeling. Data modeled included maternal anemia in rabbits, delayed ossification in rabbits and rats, and decreased maternal body weight gain in rats (see Tables A-10, A-11, and A-12); data for neurological effects were not adequate for modeling due to qualitative and/or incomplete quantitative reporting. The data were fit to all available dichotomous or continuous models in EPA’s BMDS (version 3.1.2) using a BMR of 1 standard deviation (hematological data), 10% relative deviation (body weight data), or 5% extra risk (developmental endpoints). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMDLs estimated from these models was ≥3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen.

Table A-10 Maternal Anemia in New Zealand Rabbits Following Gavage Administration of 1,2-Dichloropropane on GDs 7–19

| Dose (mg/kg/day)
| 0 | 25 | 100 | 250
Maternal reticulocyte counts | 2.1±1.2 | 2.5±0.4 | 4.5±1 | 7.8±1.5
Mean ± SD (N) | (4) | (3) | (5) | (3)

GD = gestation day; N = number; SD = standard deviation

Source: Berdasco et al. 1988

Table A-11 Maternal Anemia and Incidence of Delayed Ossification in New Zealand Rabbits Following Gavage Administration of 1,2-Dichloropropane on GDs 7–19

| Dose (mg/kg/day)
| 0 | 15 | 50 | 150
Maternal reticulocyte counts | 3.2±0.6 | 3.6±0.7 | 3.8±0.9 | 6.7±1.7
Mean ± SD (N) | (18) | (16) | (17) | (15)
Delayed ossification | 0/18 | 0/16 | 2/17 | 6/15
Litter incidence (% incidence) | (0%) | (0%) | (12%) | (40%)

GD = gestation day; N = number; SD = standard deviation

Source: Kirk et al. 1995

Table A-12 Maternal Body Weight Gain and Incidence of Delayed Ossification in Sprague-Dawley Rats Following Gavage Administration of 1,2-Dichloropropane on GDs 6–15

| Dose (mg/kg/day)
| 0 | 10 | 30 | 125
Maternal body weight gain (g) | 189.2±30 | 188.8±23.7 | 188.7±23.5 | 170.5±23.7
Mean ± SD (N) | (25) | (28) | (28) | (30)
Delayed ossification | 8/25 | 8/28 | 10/28 | 16/30
Litter incidence (% incidence) | (32%) | (29%) | (36%) | (53%)

GD = gestation day; N = number; SD = standard deviation

Source: Kirk et al. 1995

Suitable models were not identified for delayed ossification data in rabbits or rats (Kirk et al. 1995). Models produced questionable results, providing BMDL values that were inconsistent with empirical data (values of 5.6 and 10 mg/kg/day, respectively, were substantially lower than two no-effect dose levels in both studies). Therefore, ATSDR used the NOAEL/LOAEL approach for this endpoint.

For maternal anemia in rabbits reported by Berdasco et al. (1998), seven frequentist, constant variance models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The unrestricted Linear model estimated a BMD_1SD_ and BMDL_1SD_ of 41 and 30 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-13.

Table A-13 Model Predictions (Constant Variance) for Maternal Reticulocyte Count in Pregnant New Zealand White Rabbits Orally Administered 1,2-Dichloropropane on GDs 7–19 (Berdasco et al. 1988)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 74 | 57 | 0.29 | 49.09 | 1.16 | -0.78
Exponential (model 3)^d^ | 74 | 57 | 0.29 | 49.09 | 1.16 | -0.78
Exponential (model 4)^d^ | 38 | 22 | 0.74 | 48.69 | -0.28 | 0.16
Exponential (model 5)^d^ | | | NA | 50.58 | 0.00 | 0.00
Hill^d^ | | | NA | 50.58 | 0.00 | 0.00
Polynomial (3-degree)^e^ | 41 | 30 | 0.92 | 46.75 | -0.29 | 0.05
Polynomial (2-degree)^e^ | 41 | 30 | 0.92 | 46.75 | -0.29 | 0.05
Power^d^ | 41 | 30 | 0.92 | 46.75 | -0.29 | 0.05
Linear ^e^ ^,^ ^f^ | 41 | 30 | 0.92 | 46.75 | -0.29 | 0.05

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance models provided adequate fit to the variance data. With constant variance model applied, all models except the Exponential 5 and the Hill models provided adequate fit to the means (the Exponential 3 model converged on Exponential model 2, and Power and Polynomial models all converged upon the Linear model). BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC is selected (Linear model)

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMDL_1SD_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 1SD = exposure dose associated with a 1 standard deviation change in outcome); GD = gestation day; NA = not applicable (goodness of fit test cannot be calculated)

For maternal anemia in rabbits reported by Kirk et al. (1995), six frequentist, non-constant variance models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 2). The restricted Exponential 2 model estimated a BMD_1SD_ and BMDL_1SD_ of 37 and 30 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-14.

Table A-14 Model Predictions (Non-constant Variance) for Maternal Reticulocyte Count in Pregnant New Zealand White Rabbits Orally Administered 1,2-Dichloropropane on GDs 7–19 (Kirk et al. 1995)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2) ^d^ ^,^ ^e^ | 37 | 30 | 0.35 | 176.44 | -1.25 | -0.04
Exponential (model 3)^d^ | 47 | 30 | 0.19 | 178.05 | -0.76 | -0.43
Exponential (model 4)^d^ | | | 0.04 | 180.61 | 0.71 | 0.21
Exponential (model 5)^d^ | | | NA | 180.48 | -0.69 | -0.60
Hill^d^ | | | NA | 180.50 | -0.74 | -0.57
Polynomial (3-degree)^f^ | 49 | 27 | 0.28 | 177.52 | -0.57 | -0.41
Polynomial (2-degree)^f^ | 48 | 27 | 0.21 | 177.93 | -0.71 | -0.44
Power^d^ | 50 | 25 | 0.14 | 178.48 | -0.69 | -0.60
Linear^f^ | 29 | 22 | 0.12 | 178.60 | 0.71 | 0.23

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. Constant variance model did not fit the variance data, but non-constant variance model did. With nonconstant variance model applied, all models except for Exponential models 4 and 5, and the Hill model, provided adequate fit to means. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential model 2).

f Coefficients restricted to be positive.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMDL_1SD_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 1SD = exposure dose associated with a 1 standard deviation change in outcome); GD = gestation day; NA = not applicable (goodness of fit test cannot be calculated)

For decreased maternal body weight gain reported by Kirk et al. (1995), seven frequentist, non-constant variance models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (2-degree Polynomial). The restricted 2-degree Polynomial model estimated a BMD_RD10_ and BMDL_RD10_ of 126 and 84 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-15.

Table A-15 Model Predictions (Constant Variance) for Reduced Body Weight Gain in Female Sprague-Dawley Rats Orally Administered 1,2-Dichloropropane on GDs 6–15 (Kirk et al. 1995)

Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 120 | 80 | 0.78 | 1,033.8 | -0.14 | -0.35
Exponential (model 3)^d^ | 126 | 83 | 0.95 | 1,035.3 | 0.00 | 0.03
Exponential (model 4)^d^ | 120 | 80 | 0.78 | 1,033.8 | -0.14 | -0.35
Exponential (model 5)^d^ | | | NA | 1,037.3 | 0.00 | 0.04
Hill^d^ | | | NA | 1,037.3 | -9,999.00 | 0.04
Polynomial (3-degree)^e^ | 126 | 85 | 0.95 | 1,035.3 | 0.00 | 0.02
Polynomial (2-degree) ^e^ ^,^ ^f^ | 126 | 84 | 0.99 | 1,033.3 | -0.01 | -0.02
Power^d^ | 126 | 85 | 0.95 | 1,035.3 | 0.00 | 0.03
Linear^e^ | 120 | 82 | 0.80 | 1,033.8 | -0.12 | -0.34

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance models provided adequate fit to the variance data. With constant variance model applied, all models provided adequate fit to the means, except for the Hill and Exponential 5 models. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC is selected (2-degree Polynomial).

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMDL_RD10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., RD10 = exposure dose associated with a 10% change in outcome); GD = gestation day; NA = not applicable (goodness of fit test cannot be calculated)

Table A-16 summarized the potential candidate PODs for the acute-duration oral MRL for 1,2-dichloropropane. The lowest BMD value of 37 mg/kg/day is based on maternal anemia in rabbits (Kirk et al. 1995); this value is lower than BMD/LOAEL values associated with developmental, neurological, or body weight effects. Maternal anemia reported in the Kirk et al. (1995) and Berdasco et al. (1988) studies and delayed skull ossification in rats (Kirk et al. 1995) provided the same POD based on BMDL or NOAEL values, respectively (30 mg/kg/day). Based on adequate BMD modeling and consistency of results from two studies, maternal anemia was selected as the critical effect. For the Kirk et al. (1995) study, the Exponential 2 model fit to the hematological data in maternal rabbits is presented in Figure A-3. For the Berdasco et al. (1998) study, the Linear model fit to the hematological data in maternal rabbits is presented in Figure A-2; the 2- and 3-Degree Polynomial and Power models converge on the Linear model.

Table A-16 Candidate Points of Departure for 1,2-Dichloropropane Acute-Duration Oral MRL

Endpoint | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Maternal anemia (Kirk et al. 1995) | | | 37 | 30
Maternal anemia (Berdasco et al. 1988) | | | 41 | 30
Delayed skull ossification (rat) | 30 | 125
Delayed skull ossification (rabbit) | 50 | 150
CNS depression (Sprague-Dawley rat) | ND | 100
Clinical signs of neurotoxicity | 30 | 125
CNS depression (Wistar rat) | ND | 145
Decreased maternal body weight gain | | | 126 | 84

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD; CNS = central nervous system; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Figure A-2 Fit of Exponential Model 2 to Data for Maternal Reticulocyte Count in Pregnant New Zealand White Rabbits Orally Administered 1,2-Dichloropropane on Gestational Days 7–19 (Kirk et al. 1995)

Figure A-2 description

Figure A-3 Fit of Linear Model to Data for Maternal Reticulocyte Count in Pregnant New Zealand White Rabbits Orally Administered 1,2-Dichloropropane on Gestational Days 7–19 (Berdasco et al. 1988)

Figure A-3 description

Selection of the Principal Study: The two studies that provided identical BMCL values for the critical effect of maternal anemia were selected as co-principal studies for derivation of the acute oral MRL (Berdasco et al. 1988; Kirk et al. 1995).

Summary of the Co-Principal Studies:

Berdasco NM, Johnson KA, Hanley TRJ. 1988. Propylene dichloride: Oral teratology probe study in New Zealand white rabbits with cover letter dated 100188. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0516583. 86890000004.

Kirk HD, Berdasco NM, Breslin WJ, . 1995. Developmental toxicity of 1,2-dichloropropane (PDC) in rats and rabbits following oral gavage. Fundam Appl Toxicol 28(1):18–26.8566479

Berdasco et al. (1988) administered 1,2-dichloroporpane (99.9% pure) to groups of artificially-inseminated rabbits via gavage in corn oil at doses of 0, 25, 100, or 250 mg/kg/day on GDs 7–19. Does were sacrificed on GD 20. Maternal toxicity endpoints evaluated included mortality, clinical signs of toxicity, body weight, gross necropsy, hematology (on GD 20), organ weights (kidney, liver, spleen), and eye examination (in situ, glass slide technique). Reproductive endpoints included the number of corpora lutea and numbers and positions of implantations and resorptions.

In the high-dose group, 2/7 does died; the cause of death was undetermined. Two additional high-dose animals showed weight loss and complete litter loss. Overall body weights did not differ between control and exposed animals and the resorption rates were not significantly different between groups. There were no exposure-related changes in organ weights or gross necropsy. Several changes were observed in hematological parameters, indicating regenerative anemia, including: 22–24% decreases in erythrocyte count, hemoglobin, and hematocrit at 500 mg/kg/day; a 2–3.7-fold increase in the percentage of reticulocytes at ≥100 mg/kg/day; increased slight-to-moderate polychromasia in red blood cells at ≥100 mg/kg/day; and increased slight-to-moderate anisocytosis in red blood cells at 250 mg/kg/day.

Kirk et al. (1995) administered 1,2-dichloropropane (99.9% pure) to groups of artificially inseminated rabbits via gavage in corn oil at doses of 0, 15, 50, or 150 mg/kg/day on GDs 7–19 (18 rabbits/group). Does were sacrificed on GD 28. Maternal toxicity endpoints evaluated included mortality, clinical signs, body weight, hematology (on GD 19), and organ weights (liver, kidney, spleen, gravid uterus). Reproductive and developmental endpoints included number of corpora lutea, number and position of implantations, resorptions, and live or dead fetuses, sex and body weight of each fetus, and external, visceral, and skeletal malformations.

In the high-dose group, 2/18 does died (one due to intubation error; cause of death not reported in second doe). Intermittent anorexia was observed in 17/18 does in the high-dose group during dosing. Significantly lowered weight gains were observed in high dose rabbits during dosing (GDs 7–20), but no significant differences were observed in absolute body weight compared to controls. Evidence of regenerative anemia was observed at the high dose (decreased erythrocyte counts, hemoglobin concentration, and hematocrit and increased platelet, leukocyte, and reticulocyte counts; slight-to-moderate anisocytosis, poikilocytosis, and/or polychromasia of red blood cells observed microscopically). No organ weight changes were observed. No exposure-related changes in the number of litters or pregnancy outcomes were observed. The litter incidence of delayed ossification of the skull was significantly elevated at 150 mg/kg/day (6/15 litters, 6/140 fetuses) and non-significantly elevated at 50 mg/kg/day (2/17 litters, 2/142 fetuses), compared with controls (0/18 litters, 0/149 fetuses).

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 30 mg/kg/day for increased maternal reticulocyte counts (from both studies) was selected as the POD.

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = BMDL_1SD_ ÷ UFs
- MRL = 30 mg/kg/day ÷ (10 × 10) = 0.3 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As detailed in Appendix C, hematological effects are a presumed health effect for humans. Several human case studies reported hematological effects, including hemolytic anemia, following accidental or intentional oral exposure to high levels of 1,2-dichloropropane (Di Nucci et al. 1988; Fiaccadori et al. 2003; Lucantoni et al. 1991, 1992; Perbellini et al. 1985; Pozzi et al. 1985). In addition to the findings in maternal rabbits by Berdasco et al. (1988) and Kirk et al. (1995) following acute exposure, hemolytic anemia has also been reported following oral exposure in rats at an acute dose of 2,000 mg/kg/day (Imberti et al. 1990) and intermediate-duration doses as low as 100 mg/kg/day (Bruckner et al. 1989; Kirk et al. 1990). Evidence of hemolytic anemia was also observed in rats, mice, and rabbits following intermediate-duration inhalation exposure to concentrations as low as 150 ppm (Matsumoto et al. 2013; Nitschke et al. 1988; Umeda et al. 2010).

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.07 mg/kg/day
Critical Effect: | Hemolytic anemia
Reference: | Bruckner et al. 1989
Point of Departure: | LOAEL of 100 mg/kg/day (LOAEL_ADJ_ of 71 mg/kg/day)
Uncertainty Factor: | 1,000
LSE Graph Key: | 19
Species: | Rabbit

MRL Summary: An intermediate-duration oral MRL of 0.07 mg/kg/day was derived for 1,2-dichloropropane based on evidence of hemolytic anemia in rats exposed to doses ≥100 mg/kg/day for 13 weeks (5 days/week) (Bruckner et al. 1989). The MRL is based on the LOAEL of 100 mg/kg/day, which was adjusted to a continuous exposure (LOAEL_ADJ_) of 71 mg/kg/day for increased serum bilirubin, hemosiderosis in the spleen, and erythropoietic hyperplasia and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Several studies have evaluated the toxicity of 1,2-dichloropropane following intermediate-duration oral exposure. The most sensitive effects identified in intermediate oral studies included hematological, hepatic, and body weight effects; see Table A-17. Since all of these adverse effects occurred at similar doses, all were considered for MRL derivation.

Table A-17 Summary of Candidate Critical Effects for Intermediate Oral MRL for 1,2-Dichloropropane

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
B6C3F1 mouse | 4 weeks; 5 days/week (GO) | ND | 125 | Increased absolute liver weight | Gi et al. 2015a
B6C3F1 mouse | 4 weeks; 5 days/week (GO) | ND | 125 | Increased relative liver weight | Gi et al. 2015a
B6C3F1 mouse | 4 weeks; 5 days/week (GO) | ND | 125 | Mild fatty change | Gi et al. 2015a
Body weight effects
F344 rat | 13 weeks; 5 days/week (GO) | 65 | 200 | Decreased body weight in males | Johnson and Gorzinski 1988
Hematological effects
Sprague-Dawley rat | 13 weeks; 5 days/week (GO) | ND | 100 | Hemolytic anemia | Bruckner et al. 1989

GO = gavage (oil vehicle); LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

In order to identify the most sensitive endpoint, BMD modeling was attempted for candidate critical endpoints listed in Table A-17 when data were amenable to modeling. Data modeled included increased absolute and relative liver weight in mice and decreased body weight in rats (see Tables A-18 and A-19). The data were fit to all available continuous models in EPA’s BMDS (version 3.1.2) using a BMR of 10% relative deviation. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMDLs estimated from these models was ≥3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. Histological effects in the liver were not amenable for modeling because the incidence increased from 0% in controls to 100% in the lowest dose tested (Gi et al. 2015a). Hematological data for rats were inadequate for modeling because exact animal number per group was not reported (Bruckner et al. 1989). Therefore, a NOAEL/LOAEL approach was used for these studies.

Table A-18 Body Weight in Male F344 Rats Following Gavage Administration of 1,2-Dichloropropane for 13 Weeks

| Dose (mg/kg/day)
| 0 | 20 | 65 | 200
Terminal body weight; mean±SD (N) | 341.7±11.2 (15) | 334.9±13.7 (15) | 331.0±25.7 (15) | 308.0±14.8 (15)

N = number; SD = standard deviation

Source: Johnson and Grozinski 1988

Table A-19 Liver Weight in B6C3F1 Mice Following Gavage Administration of 1,2-Dichloropropane for 4 Weeks (Gi et al. 2015a)

| Dose (mg/kg/day)
| 0 | 125 | 250
Absolute liver weight; mean±SD (N) | 0.93±0.05 (5) | 1.04±0.03 (5) | 1.09±0.06 (5)
Relative liver weight; mean±SD (N) | 3.67±0.16 (5) | 4.03±0.20 (5) | 4.2±0.14 (5)

N = number; SD = standard deviation

Source: Gi et al. 2015a

None of the BMD models (with constant variance or nonconstant variance) provided adequate fit to the decreased body weight in male rats. Therefore, a NOAEL/LOAEL approach was used for this endpoint.

For absolute liver weight, five frequentist, constant variance models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear); the 2-Degree Polynomial and Power models converged on the Linear model. The unrestricted Linear model estimated a BMD_RD10_ and BMDL_RD10_ of 147 and 109 ppm, respectively. The results of the BMD modeling are summarized in Table A-20.

Table A-20 Model Predictions (Constant Variance) for Absolute Liver Weight in Male B6C3F1 Mice Orally Administered 1,2-Dichloropropane 5 Days/Week for 5 Weeks (Gi et al. 2015a)

Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | Scaled residuals^c^
Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 153 | 117 | 0.18 | -43.85 | 1.07 | -0.58
Exponential (model 3)^d^ | 153 | 117 | 0.18 | -43.85 | 1.07 | -0.58
Exponential (model 4)^d^ | | | NA | -43.69 | 0.00 | 0.00
Exponential (model 5)^d^ | | | <0.0001 | -41.69 | 0.00 | 0.00
Hill^d^ | | | <0.0001 | -41.69 | 0.00 | 0.00
Polynomial (2-degree)^e^ | 147 | 109 | 0.22 | -44.16 | 0.98 | -0.49
Power^d^ | 147 | 109 | 0.22 | -44.16 | 0.98 | -0.49
Linear ^e^ ^,^ ^f^ | 147 | 109 | 0.22 | -44.16 | 0.98 | -0.49

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance models provided adequate fit to the variance data. With constant variance model applied, all models provided adequate fit to the means except for the Hill and Exponential 4 and 5 models (Exponential 3 converged upon Exponential 2 and the power and 2-degree polynomial models converged upon the linear model). BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC is selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure concentration associated with a 10% change in outcome); NA = not applicable (Goodness of fit test cannot be calculated); RD = relative deviation

For relative liver weight, five frequentist, constant variance models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear); the 2-Degree Polynomial and Power models converged on the Linear model. The unrestricted Linear model estimated a BMD_RD10_ and BMDL_RD10_ of 175 and 129 ppm, respectively. The results of the BMD modeling are summarized in Table A-21.

Table A-21 Model Predictions (Constant Variance) for Relative Liver Weight in Male B6C3F1 Mice Orally Administered 1,2-Dichloropropane 5 Days/Week for 5 Weeks (Gi et al. 2015a)

Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | Scaled residuals^c^
Model | BMD_RD10_^a^ (mg/kg/day) | BMDL_RD10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 180 | 135 | 0.22 | -6.70 | 0.97 | -0.52
Exponential (model 3)^d^ | 180 | 135 | 0.22 | -6.70 | 0.97 | -0.52
Exponential (model 4)^d^ | | | NA | -6.20 | 0.00 | 0.00
Exponential (model 5)^d^ | | | NA | -6.20 | 0.00 | 0.00
Hill^d^ | | | <0.0001 | -4.20 | 0.00 | 0.00
Polynomial (2-degree)^e^ | 175 | 129 | 0.26 | -6.93 | 0.90 | -0.45
Power^d^ | 175 | 129 | 0.26 | -6.93 | 0.90 | -0.45
Linear ^e^ ^,^ ^f^ | 175 | 129 | 0.26 | -6.93 | 0.90 | -0.45

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance model provided adequate fit to the variance data. With constant variance model applied, all models except Exponential 4, provided adequate fit to means (Exponential 3 converged upon Exponential 2 and the power and 2-degree polynomial models converged upon the linear model). BMDLs for models providing adequate fit were sufficiently close (differed by <2–3-fold), so the model with the lowest AIC was selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure concentration associated with a 10% change in outcome); NA = not applicable (Goodness of fit test cannot be calculated); RD = relative deviation

Table A-22 summarizes the potential candidate PODs for the intermediate-duration oral MRL for 1,2-dichloropropane. Based on the lowest available PODs, hematological effects (hemolytic anemia) were identified as the critical effect for following intermediate-duration oral exposure to 1,2-dichloropropane.

Table A-22 Candidate Points of Departure 1,2-Dichloropropane Acute-Duration Oral MRL

Endpoint | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Increased absolute liver weight | | | 145 | 109
Increased relative liver weight | | | 175 | 129
Mild fatty liver change | ND | 125
Decreased body weight | 65 | 200
Hemolytic anemia | ND | 100

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level;

Selection of the Principal Study: The study with the lowest identified LOAEL for the critical effect of hemolytic anemia was selected as the principal study (Bruckner et al. 1989).

Summary of the Principal Study:

Bruckner JV, MacKenzie WF, Ramanathan R, . 1989. Oral toxicity of 1,2-dichloropropane: Acute, short-term, and long-term studies in rats. Fundam Appl Toxicol 12(4):713–730.2744274

Groups of Sprague-Dawley rats were administered 1,2-dichloropropane (99% pure) via gavage in corn oil at doses of 0, 100, 250, 500, or 750 mg/kg/day for 13 weeks (5 days/week). Endpoints evaluated included mortality, clinical signs, body weight, serum chemistry, urinalysis, liver and kidney weight, and histology (liver, kidneys, lungs, brain, adrenals, spleen, stomach, testis, epididymis).

High mortality was observed in the 750 mg/kg/day group, with ~55% mortality within 10 days. The remaining animals were sacrificed moribund. By the end of the 13-week exposure period, >50% of the rats treated with 500 mg/kg/day had died. Survival was at least 90% in remaining groups. The 500 mg/kg/day group showed pronounced CNS depression, but no brain lesions were observed in any groups. Body weight gain was significantly decreased in a dose-related manner in all treatment groups throughout the study. Liver effects were seen only at 500 mg/kg/day and included periportal vacuolization and active fibroplasia. Evidence of hemolytic anemia was seen at all doses and was dose-related in severity. At 100 mg/kg/day, serum bilirubin was increased, and hemosiderosis in the spleen and erythropoietic hyperplasia were seen. At 250 mg/kg/day, hemosiderosis in the liver and kidney was also observed. Increased fat storage in the adrenal cortex was observed at 500 mg/kg/day; vacuolization of the adrenal medulla and lipidosis of the adrenal cortex were also observed in high-dose animals sacrificed moribund on day 10. Testicular effects seen at 500 mg/kg/day included degeneration, reduced sperm production, accumulation of spermatid giant cells, increased number of degenerate spermatogonia, and reduced number of sperm in epididymides. No such effects were observed at 100 or 250 mg/kg/day.

Selection of the Point of Departure for the MRL: The LOAEL of 100 mg/kg/day for hemolytic anemia was selected as the POD.

Adjustment for Intermittent Exposure: The LOAEL was adjusted from intermittent exposure to account for a continuous exposure scenario:

- LOAEL_ADJ_ = 100 mg/kg/day × 5 days/7 days = 71 mg/kg/day

Uncertainty Factor: LOAEL_ADJ_ is divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = LOAEL_ADJ_ ÷ UFs
- MRL = 71 mg/kg/day ÷ (10 × 10 × 10) = 0.07 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As discussed in the acute oral MRL worksheet, hemolytic anemia has been reported in several human case reports (Di Nucci et al. 1988; Fiaccadori et al. 2003; Lucantoni et al. 1991, 1992; Perbellini et al. 1985; Pozzi et al. 1985) and following inhalation and oral exposure in laboratory animals (Berdasco et al. 1988, Bruckner et al. 1989; Imberti et al. 1990; Kirk et al. 1990, 1995; Matsumoto et al. 2013; Nitschke et al. 1988; Umeda et al. 2010). Systematic review of available data indicates that hematological effects are a presumed health effect for humans (see Appendix C).

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloropropane
CAS Numbers: | 78-87-5
Date: | November 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: A chronic-duration oral MRL was not derived due to lack of adequate data for the critical effect of anemia (identified in acute- and intermediate-duration oral studies). Available chronic studies did not assess hematological parameters. Derivation of a chronic-duration oral MRL based on the lowest LOAEL identified in the available chronic studies (body weight effects) results in an MRL that is higher than the intermediate-duration oral MRL based on hematological effects and may not be protective of hematological effects. Thus, the chronic database was not considered adequate for derivation of a chronic oral MRL. Since it is unknown if hematological effects would occur at lower doses with longer exposure durations, it is considered inappropriate to base the chronic MRL on intermediate-duration data. Therefore, we cannot be sure that the intermediate MRL would be protective for chronic exposure.

Two studies evaluated the toxicity of 1,2-dichloropropane following chronic-duration oral exposure: one in rats and one in mice. The most sensitive effects identified in these studies included hepatic effects, hemosiderosis of the spleen, and body weight effects (see Table A-23). The data for these effects were not suitable for modeling. The lowest LOAEL identified was 125 mg/kg/day for body weight effects in male rats (NTP 1986); the associated NOAEL of 65 mg/kg/day would be the most sensitive POD.

After adjustment for intermittent exposure (65 mg/kg/day × 5 days/7 days), the NOAEL_ADJ_ of 46 mg/kg/day divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) would result in a chronic MRL of 0.5 mg/kg/day. This candidate MRL is almost 10-fold higher than the MRL derived for intermediate-duration oral exposure.

Table A-23 Summary of Candidate Critical Effects for Chronic Oral MRL for 1,2-Dichloropropane

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
F344 rat | 104 weeks; 5 days/week (GO) | 62 | 125 | Decreased body weight in males | NTP 1986
Hepatic effects
F344 rat | 104 weeks; 5 days/week (GO) | 125 | 250 | Clear cell foci and necrosis | NTP 1986
B6C3F1 mouse | 104 weeks; 5 days/week (GO) | 125 | 250 | Hepato-cytomegaly and necrosis in males | NTP 1986
Hematological effects
F344 rat | 104 weeks; 5 days/week (GO) | 125 | 250 | Slight hemosiderosis of the spleen in females (blood hematological parameters not evaluated) | NTP 1986

GO = gavage (oil vehicle); LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Carolyn Harper