# CHAPTER 8 REFERENCES

Abdellatif AG, Preat V, Vamecq J, . 1990. Peroxisome proliferation and modulation of rat liver carcinogenesis by 2,4-dichlorophenoxyacetic acid, 2,4,5-trichlorophenoxyacetic acid, perfluorooctanoic acid and nafenopin. Carcinogenesis 11(11):1899–1902.2225320
Ahmadi F, Bakhshandeh F. 2009. In vitro study of damaging effects of 2,4-dichlorophenoxyacetic acid on DNA structure by spectroscopic and voltammetric techniques. DNA Cell Biol 28(10):527–533. 10.1089/dna.2009.0892.19563251
Ahmed FE, Hart RW, Lewis NJ. 1977. Pesticide induced DNA damage and its repair in cultured human cells. Mutat Res 42(2):161–174.190533
Alavanja MCR, Samanic C, Dosemeci M, . 2003. Use of agricultural pesticides and prostate cancer risk in the agricultural health study cohort. Am J Epidemiol 57(9):800–814.
Alexander BH, Mandel JS, Baker BA, . 2007. Biomonitoring of 2,4-dichlorophenoxyacetic acid exposure and dose in farm families. Environ Health Perspect 115(3):370–376. 10.1289/ehp.8869.17431485
Amer SM, Aly FA. 2001. Genotoxic effect of 2,4-dichlorophenoxy acetic acid and its metabolite 2,4-dichlorophenol in mouse. Mutat Res 494(1–2):1–12.11423340
Andreotti G, Beane Freeman LE, Hou L, . 2009. Agricultural pesticide use and pancreatic cancer risk in the Agricultural Health Study cohort. Int J Cancer 124(10):2495–2500.19142867
Andreotti G, Hoppin JA, Hou L, . 2015. Pesticide use and relative leukocyte telomere length in the Agricultural Health Study. PLoS ONE 10(7):1–10.
Aprea C, Sciarra G, Bozzi N. 1997. Analytical methods for the determination of urinary 2,4-dichlorophenoxyacetic acid and 2-methyl-4-chlorophenoxyacetic acid in occupationally exposed subjects and in the general population. J Anal Toxicol 21(4):262–267.9248942
Arbuckle TE, Lin Z, Mery LS. 1999. Exposure to phenoxy herbicides and the risk of spontaneous abortion. Epidemiology 10:752–760.10535791
Arbuckle TE, Bruce D, Ritter L, . 2001. An exploratory analysis of the effect of pesticide exposure on the risk of spontaneous abortion in an Ontario farm population. Environ Health Perspect 109(8):851–857.11564623
Arbuckle TE, Savitz DA, Mery LS, . 2006. Indirect sources of herbicide exposure for families on Ontario farms. J Expo Sci Environ Epidemiol 16(1):98–104. 10.1038/sj.jea.7500441.16015277
Arcury TA, Grzywacz JG, Barr DB, . 2007. Pesticide urinary metabolite levels of children in eastern North Carolina farmworker households. Environ Health Perspect 115(8):1254–1260. 10.1289/ehp.9975.17687456
Arcury TA, Grzywacz JG, Talton JW, . 2010. Repeated pesticide exposure among North Carolina migrant and seasonal farmworkers. Am J Ind Med 53(8):802–813. 10.1002/ajim.20856.20623661
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles: Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2019. National Priorities List (NPL) data: 2,4-D. Agency for Toxic Substances and Disease Registry. https://www.epa.gov/superfund/superfund-national-priorities-list-npl. July 20, 2018.
Aylward LL, Morgan MK, Arbuckle TE, . 2010. Biomonitoring data for 2,4-dichlorophenoxyacetic acid in the United States and Canada: Interpretation in a public health risk assessment context using biomonitoring equivalents. Environ Health Perspect 118(2):177–181. 10.1289/ehp.0900970.20123603
Badawi AF, Cavalieri EL, Rogan EG. 2000. Effect of chlorinated hydrocarbons on expression of cytochrome P450 1A1, 1A2 and 1B1 and 2- and 4-hydroxylation of 17beta-estradiol in female Sprague-Dawley rats. Carcinogenesis 21(8):1593–1599.10910964
Bakke B, De Roos AJ, Barr DB, . 2009. Exposure to atrazine and selected non-persistent pesticides among corn farmers during a growing season. J Expo Sci Environ Epidemiol 19(6):544–554. 10.1038/jes.2008.53.19052531
Band PR, Abanto Z, Bert J, . 2011. Prostate cancer risk and exposure to pesticides in British Columbia farmers. Prostate 71(2):168–183. 10.1002/pros.21232.20799287
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bartley TJ, Hattrup AJ. 1970. 2,4-D contamination and persistence in irrigation water. Proc West Soc Weed Sci 23:10–33.
Baur JR, Bovey RW. 1974. Ultraviolet and volatility loss of herbicides. Arch Environ Contam Toxicol 2(3):275–288.4418093
Beard JD, Hoppin JA, Richards M, . 2013. Pesticide exposure and self-reported incident depression among wives in the Agricultural Health Study. Environ Res 126:31–42.23916637
Becher H, Flesch-Janys D, Kauppinen T, . 1996. Cancer mortality in German male workers exposed to phenoxy herbicides and dioxins. Cancer Causes Control 7(3):312–321.8734824
Bergesse JR, Balegno HF. 1995. 2,4-Dichlorophenoxyacetic acid influx is mediated by an active transport system in Chinese hamster ovary cells. Toxicol Lett 81(2–3):167–173.8553371
Berkley MC, Magee KR. 1963. Neuropathy following exposure to a dimethylamine salt of 2,4-D. Arch Intern Med 111(3):351–352. 10.1001/archinte.1963.03620270077012.13970845
Berndt WO, Koschier F. 1973. In vitro uptake of 2,4-dichlorophenoxyacetic acid (2,4-D) and 2,4,5-trichlorophenoxyacetic acid (2,4,5-T) by renal cortical tissue of rabbits and rats. Toxicol Appl Pharmacol 26(4):559–570.4771605
Berwick P. 1970. 2,4-Dichlorophenoxyacetic acid poisoning in man: Some interesting clinical and laboratory findings. J Am Med Assoc 214(6):1114–1117.
Beseler C, Stallones L, Hoppin JA, . 2006. Depression and pesticide exposures in female spouses of licensed pesticide applicators in the Agricultural Health Study cohort. J Occup Environ Med 48(10):1005–1013.17033500
Bhatti P, Blair A, Bell EM, . 2010. Predictors of 2,4-dichlorophenoxyacetic acid exposure among herbicide applicators. J Expo Sci Environ Epidemiol 20(2):160–168. 10.1038/jes.2009.14.19319162
Bidleman TE. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22(4):361–367.
Bloemen LJ, Mandel JS, Bond GG, . 1993. An update of mortality among chemical workers potentially exposed to the herbicide 2,4-dichlorophenoxyacetic acid and its derivatives. J Occup Med 35(12):1208–1212.8113924
Boers D, Portengen L, Bueno-de-Mesquita HB, . 2010. Cause-specific mortality of Dutch chlorophenoxy herbicide manufacturing workers. Occup Environ Med 67(1):24–31. 10.1136/oem.2008.044222.19736176
Bond GG, Wetterstroem NH, Roush GJ, . 1988. Cause specific mortality among employees engaged in the manufacture, formulation, or packaging of 2,4-dichlorophenoxyacetic acid and related salts. Br J Ind Med 45(2):98–105.3342201
Bortolozzi AA, Duffard RO, Evangelista De Duffard AM. 1999. Behavioral alterations induced in rats by a pre- and postnatal exposure to 2,4-dichlorophenoxyacetic acid. Neurotoxicol Teratol 21(4):451–465.10440489
Bortolozzi A, Duffard R, Evangelista De Duffard AM. 2003. Asymmetrical development of the monoamine systems in 2,4-dichlorophenoxyacetic acid treated rats. Neurotoxicology 24(1):149–157.12564390
Bortolozzi A, Duffard RO, Rubio M, . 1998. Regionally specific changes in central brain monoamine levels by 2,4-dichlorophenoxyacetic acid in acute treated rats. Neurotoxicology 19(6):839–851.9863773
Bortolozzi A, Evangelista de Duffard AM, Dajas F, . 2001. Intracerebral administration of 2,4-diclorophenoxyacetic acid induces behavioral and neurochemical alterations in the rat brain. Neurotoxicology 22(2):221–232.11405254
Bortolozzi A, Duffard R, Antonelli M, . 2002. Increased sensitivity in dopamine D2-like brain receptors from 2,4-dichlorophenoxyacetic acid (2,4-D)-exposed and amphetamine-challenged rats. Ann N Y Acad Sci 965:314–323.12105107
Bortolozzi AA, Evangelista De Duffard AM, Duffard RO, . 2004. Effects of 2,4-dichlorophenoxyacetic acid exposure on dopamine D2-like receptors in rat brain. Neurotoxicol Teratol 26(4):599–605. 10.1016/j.ntt.2004.04.001.15203183
Botre C, Botre F, Mazzei F. 2000. Inhibition-based biosensors for the detection of environmental contaminants: Determination of 2,4-dichlorophenoxyacetic acid. Environ Toxicol Chem 19(12):2876–2881.
Bradberry SM, Watt BE, Proudfoot AT, . 2000. Mechanisms of toxicity, clinical features, and management of acute chlorophenoxy herbicide poisoning: A review. J Toxicol Clin Toxicol 38(2):111–122.10778907
Brand RM, Spalding M, Mueller C. 2002. Sunscreens can increase dermal penetration of 2,4-dichlorophenoxyacetic acid. J Toxicol Clin Toxicol 40(7):827–832.12507050
Brand RM, Jendrzejewski JL, Charron AR. 2007a. Potential mechanisms by which a single drink of alcohol can increase transdermal absorption of topically applied chemicals. Toxicology 235(3):141–149. 10.1016/j.tox.2007.03.008.17467136
Brand RM, Pike J, Wilson RM, . 2003. Sunscreens containing physical UV blockers can increase transdermal absorption of pesticides. Toxicol Ind Health 19(1):9–16.15462532
Brand RM, Charron AR, Dutton L, . 2004. Effects of chronic alcohol consumption on dermal penetration of pesticides in rats. J Toxicol Environ Health A 67(2):153–161. 10.1080/15287390490264794.14675904
Brand RM, McMahon L, Jendrzejewski JL, . 2007b. Transdermal absorption of the herbicide 2,4-dichlorophenoxyacetic acid is enhanced by both ethanol consumption and sunscreen application. Food Chem Toxicol 45(1):93–97. 10.1016/j.fct.2006.08.005.17030379
Brown LM, Burmeister LF, Everett GD, . 1993. Pesticide exposures and multiple myeloma in Iowa men. Cancer Causes Control 4(2):153–156.8481493
Brusco A, Saavedra JP, Garcia G, . 1997. 2,4-Dichlorophenoxyacetic acid through lactation induces astrogliosis in rat brain. Mol Chem Neuropathol 30(3):175–185.9165484
Bucheli TD, Mueller SR, Heberle S, . 1998. Occurrence and behavior of pesticides in rainwater, roof runoff, and artificial stormwater infiltration. Environ Sci Technol 32(22):3457–3464.
Bueno De Mesquita HB, Doornbos G, Van Der Kuip DA, . 1993. Occupational exposure to phenoxy herbicides and chlorophenols and cancer mortality in the Netherlands. Am J Ind Med 23(2):289–300.8427257
Bugbee GJ, White JC, Krol WJ. 2003. Control of variable watermilfoil in Bashan Lake, CT with 2,4-D: Monitoring of lake and well water. J Aquat Plant Manage 41:18–25.
Buist SCN, Cherrington NJ, Choudhuri S, . 2002. Gender-specific and developmental influences on the expression of rat organic anion transporters. J Pharmacol Exp Ther 301(1):145–151.11907168
Burns CJ, Swaen GM. 2012. Review of 2,4-dichlorophenoxyacetic acid (2,4-D) biomonitoring and epidemiology. Crit Rev Toxicol 42(9):768–786. 10.3109/10408444.2012.710576.22876750
Burns CJ, Beard KK, Cartmill JB. 2001. Mortality in chemical workers potentially exposed to 2,4-dichlorophenoxyacetic acid (2,4-D) 1945-94: An update. Occup Environ Med 58(1):24–30.11119631
Burns C, Bodner K, Swaen G, . 2011. Cancer incidence of 2,4-D production workers. Int J Environ Res Public Health 8(9):3579–3590. 10.3390/ijerph8093579.22016704
Cantor KP, Blair A, Everett G, . 1992. Pesticides and other agricultural risk factors for non-Hodgkin’s lymphoma among men in Iowa and Minnesota. Cancer Res 52(9):2447–2455.1568215
Carlo GL, Cole P, Miller AB, . 1992. Review of a study reporting an association between 2,4-dichlorophenoxyacetic acid and canine malignant lymphoma: Report of an expert panel. Regul Toxicol Pharmacol 16(3):245–252.1293641
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/pdf/fourthreport.pdf. August 27, 2015.
CDC. 2012. 2,4-D; Order denying NRDC’s petition to revoke tolerances. 40 CFR Part 180. Fed Regist 77(75):23135–23158.
CDC. 2013. Fourth national report on human exposure to environmental chemicals, updated tables. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/. September 21, 2015.
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. December 14, 2015.
CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables. January 2019. Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. 17–22, 27. https://www.cdc.gov/exposurereport/. May 5, 2019.
Chamberlain E, Shi H, Wang T, . 2012. Comprehensive screening study of pesticide degradation via oxidation and hydrolysis. J Agric Food Chem 60(1):354–363. 10.1021/jf2033158.22141915
Charles JM, Bond DM, Jeffries TK, . 1996a. Chronic dietary toxicity/oncogenicity studies on 2,4-dichlorophenoxyacetic acid in rodents. Fundam Appl Toxicol 33(2):166–172.8921335
Charles JM, Cunny HC, Wilson RD, . 1996b. Comparative subchronic studies on 2,4-dichlorophenoxyacetic acid, amine, and ester in rats. Fundam Appl Toxicol 33(2):161–165.8921334
Charles JM, Dalgard DW, Cunny HC, . 1996c. Comparative subchronic and chronic dietary toxicity studies on 2,4-dichlorophenoxyacetic acid, amine, and ester in the dog. Fundam Appl Toxicol 29(1):78–85.8838642
Charles JM, Cunny HC, Wilson RD, . 1999a. Ames assays and unscheduled DNA synthesis assays on 2,4-dichlorophenoxyacetic acid and its derivatives. Mutat Res 444(1):207–216.10477356
Charles JM, Cunny HC, Wilson RD, . 1999b. In vivo micronucleus assays on 2,4-dichlorophenoxyacetic acid and its derivatives. Mutat Res 444(1):227–234.10477358
Charles JM, Hanley TR, Wilson RD, . 2001. Developmental toxicity studies in rats and rabbits on 2,4-dichlorophenoxyacetic acid and its forms. Toxicol Sci 60(1):121–131.11222879
Chaturvedi AK, Kuntz DJ, Rao NGS. 1991. Metabolic aspects of the toxicology of mixtures of parathion, toxaphene and/or 2,4-D in mice. J Appl Toxicol 11(4):245–251.1658105
Chernoff N, Setzer RW, Miller DB, . 1990. Effects of chemically induced maternal toxicity on prenatal development in the rat. Teratology 42(6):651–658. 10.1002/tera.1420420610.2087686
Clausen M, Leier G, Witte I. 1990. Comparison of the cytotoxicity and DNA-damaging properties of 2,4-D and U 46 D fluid (dimethylammonium salt of 2,4-D). Arch Toxicol 64(6):497–501.2275605
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cocco P, Satta G, Dubois S, . 2013. Lymphoma risk and occupational exposure to pesticides: Results of the epilymph study. Occup Environ Med 70(2):91–98. 10.1136/oemed-2012-100845.23117219
Coggon D, Pannett B, Winter P. 1991. Mortality and incidence of cancer at four factories making phenoxy herbicides. Br J Ind Med 48(3):173–178.2015208
Cohen S, Svrjcek A, Durborow T, . 1999. Water quality impacts by golf courses. J Environ Qual 28(3):798–809.
Collins TF, Williams CH. 1971. Teratogenic studies with 2,4,5-T and 2,4-D in the hamster. Bull Environ Contam Toxicol 6(6):559–567.5317286
Colt JS, Lubin J, Camann D, . 2004. Comparison of pesticide levels in carpet dust and self-reported pest treatment practices in four US sites. J Expo Anal Environ Epidemiol 14(1):74–83. 10.1038/sj.jea.7500307.14726946
Crosby DG, Tutass HO. 1966. Photodecomposition of 2,4-dichlorophenoxyacetic acid. J Agric Food Chem 14(6):596–599.
Curwin BD, Hein MJ, Sanderson WT, . 2005a. Urinary and hand wipe pesticide levels among farmers and nonfarmers in Iowa. J Expo Anal Environ Epidemiol 15(6):500–508. 10.1038/sj.jea.7500428.15841098
Curwin BD, Hein MJ, Sanderson WT, . 2005b. Pesticide contamination inside farm and nonfarm homes. J Occup Environ Hyg 2(7):357–367. 10.1080/15459620591001606.16020099
De Roos AJ, Zahm SH, Cantor KP, . 2003. Integrative assessment of multiple pesticides as risk factors for non-Hodgkin’s lymphoma among men. Occup Environ Med 60:E11.12937207
De Roos AJ, Cooper GS, Alavanja MC, . 2005. Rheumatoid arthritis among women in the Agricultural Health Study: Risk associated with farming activities and exposures. Ann Epidemiol 15:762–770.16257361
Dhillon AS, Tarbutton GL, Levin JL, . 2008. Pesticide/environmental exposures and Parkinson’s disease in east Texas. J Agromedicine 13(1):37–48.19042691
Dickow LM, Podell M, Gerken DF. 2000. Clinical effects and plasma concentration determination after 2,4-dichlorophenoxyacetic acid 200 mg/kg administration in the dog. J Toxicol Clin Toxicol 38(7):747–753.11192461
Dinamarca VM, Hidalgo ME, Cavieres MF. 2007. Lack of effects of 2,4-dichlorophenoxyacetic acid administration on markers of oxidative stress during early pregnancy in mice. Toxicology 237(1–3):104–110. 10.1016/j.tox.2007.05.002.17582670
DOE. 2018a. Protective Actions Criteria (PAC): Definitions of terminology. U.S. Department of Energy. https://sp.eota.energy.gov/pac/. May 16, 2019.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. May 16, 2019.
Donald DB, Cessna AJ, Sverko E, . 2007. Pesticides in surface drinking-water supplies of the northern Great Plains. Environ Health Perspect 115(8):1183–1191. 10.1289/ehp.9435.17687445
Doucette WJ. 2000. Soil and sediment sorption coefficients. In: Boethling RS, MacKay D, eds. Handbook of property estimation methods for chemicals. Environmental and health sciences. Boca Raton, FL: Lewis Publishers, 141–188.
Draper WM. 1982. A multiresidue procedure for the determination and confirmation of acidic herbicide residues in human urine. J Agric Food Chem 30(2):227–231.
Drill VA, Hiratzka T. 1953. Toxicity of 2,4-dichlorophenoxyacetic acid and 2,4,5-trichlorophenoxyacetic acid. A report on their acute and chronic toxicity in dogs. AMA Arch Ind Hyg Occup Med 7(1):61–67.13007202
Dudley AWJ, Thapar NT. 1972. Fatal human ingestion of 2,4-D, a common herbicide. Arch Pathol 94(3):270–275.5051650
Duff RM, Kissel JC. 1996. Effect of soil loading on dermal absorption efficiency from contaminated soils. J Toxicol Environ Health 48(1):93–106. 10.1080/009841096161492.8637061
Duffard R, Garcia G, Rosso S, . 1996. Central nervous system myelin deficit in rats exposed to 2,4-dichlorophenoxyacetic acid throughout lactation. Neurotoxicol Teratol 18(6):691–696.8947946
Duggan RE, Corneliussen PE, Duggan MB, . 1983. Pesticide residue levels in foods in the United States from July 1, 1969 to June 30, 1976: Summary. J Assoc Off Anal Chem 66(6):1534–1535.6643370
Durakovic Z, Durakovic A, Durakovic S, . 1992. Poisoning with 2,4-dichlorophenoxyacetic acid treated by hemodialysis. Arch Toxicol 66(7):518–521.1444815
Durkin P, Hertzberg R, Diamond G. 2004. Application of PBPK model for 2,4-D to estimates of risk in backpack applicators. Environ Toxicol Pharmacol 16(1–2):73–91. 10.1016/j.etap.2003.09.003.21782695
Eder G, Weber K. 1980. Chlorinated phenols in sediments and suspended matter of the Weser estuary. Chemosphere 9(2):111–119.
Ekstrom AM, Eriksson M, Hansson L, . 1999. Occupational exposures and risk of gastric cancer in a population-based case-control study. Cancer Res 59:5932–5937.10606238
Ellgehausen H, Guth JA, Esser HO. 1980. Factors determining the bioaccumulation potential of pesticides in the individual compartments of aquatic food chains. Ecotoxicol Environ Saf 4:134–157.7389634
Elo HA, Ylitalo P. 1979. Distribution of 2-methyl-4-chlorophenoxyacetic acid and 2,4-dichlorophenoxyacetic acid in male rats: Evidence for the involvement of the central nervous system in their toxicity. Toxicol Appl Pharmacol 51(3):439–446.538756
Elo HA, Hervonen H, Ylitalo P. 1988. Comparative study on cerebrovascular injuries by three chlorophenoxyacetic acids (2,4-D, 2,4,5-T and MCPA). Comp Biochem Physiol C 90(1):65–68.2904874
Engel LS, Hill DA, Hoppin JA, . 2005. Pesticide use and breast cancer risk among farmers’ wives in the Agricultural Health Study. Am J Epidemiol 161(2):121–135.15632262
Ensminger MP, Budd R, Kelley KC, . 2013. Pesticide occurrence and aquatic benchmark exceedances in urban surface waters and sediments in three urban areas of California, USA, 2008-2011. Environ Monit Assess 185(5):3697–3710. 10.1007/s10661-012-2821-8.22899460
EPA. 1976. Effects, uptake, and metabolism of methoxychlor, mirex, and 2,4-D in seaweeds. Gulf Breeze, FL: U.S. Environmental Protection Agency. EPA600376048.
EPA. 1980. Adsorption, movement, and biological degradation of large concentrations of selected pesticides in soils. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 1982. Retention and transformations of selected pesticides and phosphorus in soil-water systems: A critical review. Athens, GA: U.S. Environmental Protection Agency. EPA600S382060.
EPA. 1984. Memorandum: Review of subchronic feeding studies in mice and rats for inclusion in 2,4-D file. [Releasable agency review for MRID 00131303 and 00131304]. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1985. Memorandum: Accession No. No. 254708. Interim 52-week report on 2,4-D acid (2,4-dichlorophenoxy acetic acid). Chronic feeding/oncogenicity study in rats submitted by the 2,4-D industry task force on research data. [Releasable agency review for MRID 00160876]. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1986. Data evaluation report. Effects of 2,4-D on two-generations of reproduction in rats. [Releasable agency review for MRID 00150557]. U.S. Environmental Protection Agency.
EPA. 1987a. Data evaluation report: Oncogenicity study in mice with 2,4-dichlorophenoxy-acetic acid (2,4-D). [Releasable agency review for MRID 40061801]. U.S. Environmental Protection Agency.
EPA. 1987b. Data evaluation report. Addendum to the study of 2,4-D on two-generations of reproduction in rats: Correction to histopathology of the kidneys. [Releasable agency for MRID 00163996]. U.S. Environmental Protection Agency.
EPA. 1988a. Pesticides in ground water data base 1988 interim report. U.S. Environmental Protection Agency. http://nepis.epa.gov/Adobe/PDF/2000O1PT.PDF. September 22, 2015.
EPA. 1991a. 21-Day dermal irritation and dermal toxicity study in rabbits with 2,4-dichlorophenoxyacetic acid. [Releasable agency review for MRID 41735301 and 41735301]. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1991b. Puget Sound Pesticide Reconnaissance Survey, 1990. Seattle, WA: U.S. Environmental Protection Agency. 125. http://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=9100YQ44.PDF. October 1, 2015.
EPA. 1992. Data evaluation report. 2,4-Dichlorophenoxyacetic acid: Generic data submission as required in the 2,4-D registration standard. [Releasable agency review for MRID 42232701]. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1995a. Method 515.1. Determination of chlorinated acids in water by gas chromatography with an electron capture detector. Cincinnati, OH: U.S. Environmental Protection Agency, National Exposure Research Laboratory, Office of Research and Development. 515.511-511–515.511-534. https://owpubauthor.epa.gov/scitech/methods/cwa/bioindicators/upload/2007_11_06_methods_method_515_1.pdf. September 25, 2015.
EPA. 1996a. Data evaluation record. Combined chronic toxicity/carcinogenicity study on 2,4-dichlorophenoxyacetic acid (2,4-D). U.S. Environmental Protection Agency.
EPA. 1996b. Data Evaluation Record. Carcinogenicity study - mice. 2,4-Dichlorophenoxyacetic acid (2,4-D) [MRIDs evaluated: 43879801 & 43597201] U.S. Environmental Protection Agency.
EPA. 2004. Environmental Fate and Effects Division’s risk assessment for the Reregistration Eligibility Document for 2,4-dichlorophenoxyacetic acid (2,4-D) U.S. Environmental Protection Agency. EPA200401670003. http://www.regulations.gov/#!documentDetail;D=EPA-HQ-OPP-2004-0167-0003. January 27, 2016.
EPA. 2005a. Reregistration eligibility decision for 2,4-D. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/reregistration/REDs/24d_red.pdf. August 27, 2015.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2008. Data evaluation record. 2,4-D: Review of a 28-day subchronic inhalation toxicity study in rats via nose only exposures [MRIDs evaluated: 47398701] U.S. Environmental Protection Agency.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2012. 2012 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. March 4, 2015.
EPA. 2015a. Chemical data access tool (CDAT). 2012 Chemical data reporting (CDR), Acetic acid, 2-(2,4-dichlorophenoxy). CAS Number: 94-75-7. U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. December 7, 2015.
EPA. 2015b. Monitoring unregulated drinking water contaminants. National Contaminant Occurrence Database (NCOD). Six-Year Review 2 Contaminant Occurrence Data (1998-2005). U.S. Environmental Protection Agency. http://www.epa.gov/dwucmr/national-contaminant-occurrence-database-ncod. September 16, 2015.
EPA. 2015c. EDSP: Weight of evidence analysis of potential interaction with estrogen, androgen or thyroid pathways. Chemical: 2,4-Dichlorophenoxy acetic acid (2,4-D). Washington, DC: U.S. Environmental Protection Agency. http://www2.epa.gov/sites/production/files/2015-06/documents/24-d-030001_2015-06-29_txr0057151.pdf. August 27, 2015.
EPA. 2015d. Memorandum. 2,4-D: Data evaluation records (DERs) for EDSP tier 1 assays [MRIDs evaluated: 48317002, 48614301, 48614302, 48614303, 48614304, 48317001 & 48614305]. Washington, DC: U.S. Environmental Protection Agency.
EPA. 2016a. Registration of enlist duo. U.S. Environmental Protection Agency. https://www.epa.gov/ingredients-used-pesticide-products/registration-enlist-duo. December 6, 2016.
EPA. 2016b. Compiled Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://19january2017snapshot.epa.gov/aegl/compiled-acute-exposure-guideline-values-aegls_.html. May 17, 2019.
EPA. 2017. 2,4-D. Revised human health risk assessment for registration review. U.S. Environmental Protection Agency. EPA-HQ-OPP-2012-0330-0086. DP Barcode: D442471. https://www.regulations.gov/document?D=EPA-HQ-OPP-2012-0330-0086. May 16, 2019.
EPA. 2018. 2018 Edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. May 16, 2019.
Epstein SS, Arnold E, Andrea J, . 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
Eriksson M, Hardell L, Carlberg M, . 2008. Pesticide exposure as risk factor for non-Hodgkin lymphoma including histopathological subgroups analysis. Int J Cancer 123(7):1657–1663.18623080
Evangelista de Duffard AM, Bortolozzi A, Duffard RO. 1995. Altered behavioral responses in 2,4-dichlorophenoxyacetic acid treated and amphetamine challenged rats. Neurotoxicology 16(3):479–488.8584279
Eyres W. 2009. Water chestnut (Trapa natans L.) infestation in the Susquehanna River Watershed: Population assessment, control, and effects. Oneonta, NY: State University of New York College at Oneonta. Occasional Paper No. 44. http://www.oneonta.edu/academics/biofld/PUBS/OP/W.%20Eyres%20Thesis%202009%20OP%2044.pdf. January 26, 2016.
Fang SC, Lindstrom FT. 1980. In vitro binding of 14C-labeled acidic compounds to serum albumin and their tissue distribution in the rat. J Pharmacokinet Biopharm 8(6):583–597.7229910
Farwell SO, Robinson E, Powell WJ, . 1976. Survey of airborne 2,4-D in south-central Washington. J Air Pollut Control Assoc 26(3):224–230.1249346
Faustini A, Settimi L, Pacifici R, . 1996. Immunological changes among farmers exposed to phenoxy herbicides: Preliminary observations. Occup Environ Med 53(9):583–585.8882113
FDA. 2005. Total Diet Study Market Baskets 2004-1 through 2005-4. College Park, MD: U.S. Food and Drug Administration. 1–36. http://www.fda.gov/downloads/Food/FoodScienceResearch/TotalDietStudy/UCM291686.pdf. September 21, 2015.
FDA. 2017. Subpart B-Requirements for specific standardized beverages. U.S. Food and Drug Administration. Code of Federal Regulations. CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. May 16, 2019.
FDA. 2018. Substances added to food. Silver Spring, MD: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. May 16, 2019.
Feldmann RJ, Maibach HI. 1974. Percutaneous penetration of some pesticides and herbicides in man. Toxicol Appl Pharmacol 28(1):126–132.4853576
Ferri A, Duffard R, de Duffard AM. 2007. Selective oxidative stress in brain areas of neonate rats exposed to 2,4-dichlorophenoxyacetic acid through mother’s milk. Drug Chem Toxicol 30(1):17–30. 10.1080/01480540601017629.17364861
Ferri A, Duffard R, Sturtz N, . 2003. Iron, zinc and copper levels in brain, serum and liver of neonates exposed to 2,4-dichlorophenoxyacetic acid. Neurotoxicol Teratol 25(5):607–613.12972074
Figgs LW, Holland NT, Rothmann N, . 2000. Increased lymphocyte replicative index following 2,4-dichlorophenoxyacetic acid herbicide exposure. Cancer Causes & Control 11(4):373–380.10843448
Flower KB, Hoppin JA, Lynch CF, . 2004. Cancer risk and parental pesticide application in children of Agricultural Health Study participants. Environ Health Perspect 112(5):631–635.15064173
Fofana D, Kobae H, Oku S, . 2000. Prenatal developmental effects of pure 2,4-dichlorophenoxyacetic acid (2,4-D) on the rat. Congenit Anom (Kyoto) 40(4):287–296.
Fofana D, Kobae H, Sameshima K, . 2002. Postnatal survival of rat offspring prenatally exposed to pure 2,4-dichlorophenoxyacetic acid (2,4-D). Congenit Anom (Kyoto) 42(1):32–35.12094078
Fontana A, Prastaro C, Vineis P, . 1998. Incidence rates of lymphomas and environmental measurements of phenoxy herbicides: Ecological analysis and case-control study. Arch Environ Health 53(6):384–387.9886156
Foster RK, McKercher RB. 1973. Laboratory incubation studies of chlorophenoxyacetic acids in chernozemic soils. Soil Biol Biochem 5(3):333–337.
Frank R, Logan L. 1988. Pesticide and industrial chemical residues at the mouth of the Grand, Saugeen and Thames Rivers, Ontario, Canada 1981-1985. Arch Environ Contam Toxicol 17(6):741–754.
Freitag D, Geyer H, Kraus A, . 1982. Ecotoxicological profile analysis. VII. Screening chemicals for their environmental behavior by comparative evaluation. Ecotoxicol Environ Saf 6:60–81.6802631
Fukuyama T, Tajima Y, Ueda H, . 2009. Allergic reaction induced by dermal and/or respiratory exposure to low-dose phenoxyacetic acid, organophosphorus, and carbamate pesticides. Toxicology 261(3):152–161. 10.1016/j.tox.2009.05.014.19467290
Furman OS, Yu M, Teel AL, . 2013. Water quality parameters controlling the photodegradation of two herbicides in surface waters of the Columbia Basin, Washington. Chemosphere 93(9):1734–1741. 10.1016/j.chemosphere.2013.05.050.23800589
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10(Suppl 10):1–175.3319609
Gambini GF, Mantovani C, Pira E, . 1997. Cancer mortality among rice growers in Novara Province, northern Italy. Am J Ind Med 31(4):435–441.9093658
Garcia G, Tagliaferro P, Bortolozzi A, . 2001. Morphological study of 5-HT neurons and astroglial cells on brain of adult rats perinatal or chronically exposed to 2,4-dichlorophenoxyacetic acid. Neurotoxicology 22(6):733–741.11829407
Garcia G, Tagliaferro P, Ferri A, . 2004. Study of tyrosine hydroxylase immunoreactive neurons in neonate rats lactationally exposed to 2,4-dichlorophenoxyacetic Acid. Neurotoxicology 25(6):951–957. 10.1016/j.neuro.2004.05.004.15474613
Garcia GB, Konjuh C, Duffard RO, . 2006. Dopamine-beta-hydroxylase immunohistochemical study in the locus coeruleus of neonate rats exposed to 2,4-dichlorophenoxyacetic acid through mother’s milk. Drug Chem Toxicol 29(4):435–442. 10.1080/01480540600838058.16931444
Garrett NE, Stack HF, Waters MD. 1986. Evaluation of the genetic activity profiles of 65 pesticides. Mutat Res 168(3):301–325.3796654
Garry VF, Schreinemachers D, Harkins ME, . 1996. Pesticide appliers, biocides, and birth defects in rural Minnesota. Environ Health Perspect 104(4):394–399.8732949
Garry VF, Tarone RE, Kirsch IR, . 2001. Biomarker correlations of urinary 2,4-D levels in foresters: Genomic instability and endocrine disruption. Environ Health Perspect 109(5):495–500.
Garry VF, Harkins ME, Erickson LL, . 2002. Birth defects, season of conception, and sex of children born to pesticide applicators living in the Red River Valley of Minnesota, USA. Environ Health Perspect 110(3):441–449.12060842
Gilliom RJ, Barbash JE, Kolpin DW, . 1999. Testing water quality for pesticide pollution: U.S. Geological Survey investigations reveal widespread contamination of the nation’s water resources. Environ Sci Technol 33(7):164A–169A.
Glozier NE, Struger J, Cessna AJ, . 2012. Occurrence of glyphosate and acidic herbicides in select urban rivers and streams in Canada, 2007. Environ Sci Pollut Res Int 19(3):821–834. 10.1007/s11356-011-0600-7.21948131
Goldner WS, Sandler DP, Yu F, . 2010. Pesticide use and thyroid disease among women in the Agricultural Health Study. Am J Epidemiol 171(4):455–464.20061368
Goldner WS, Sandler DP, Yu F, . 2013. Hypothyroidism and pesticide use among male private pesticide applicators in the Agricultural Health Study. J Occup Environ Med 55(10):1171–1178. 10.1097/JOM.0b013e31829b290b.24064777
Goldstein NP, Jones PH, Brown JR. 1959. Peripheral neuropathy after exposure to an ester of dichlorophenoxyacetic acid. J Am Med Assoc 171(10):1306–1309.13850792
Gonzalez M, Soloneski S, Reigosa MA, . 2005. Genotoxicity of the herbicide 2,4-dichlorophenoxyacetic and a commercial formulation, 2,4-dichlorophenoxyacetic acid dimethylamine salt. I. Evaluation of DNA damage and cytogenetic endpoints in Chinese Hamster ovary (CHO) cells. Toxicol in Vitro 19(2):289–297. 10.1016/j.tiv.2004.10.004.15649642
Goodman JE, Loftus CT, Zu K. 2015. 2,4-dichlorophenoxyacetic acid and non-Hodgkin’s lymphoma, gastric cancer, and prostate cancer: Meta-analyses of the published literature. Ann Epidemiol 25:626–636.26066538
Gorzinski SJ, Kociba RJ, Campbell RA, . 1987. Acute, pharmacokinetic, and subchronic toxicological studies of 2,4-dichlorophenoxyacetic acid. Fundam Appl Toxicol 9(3):423–435.3692002
Graham RC, Ulery AL, Neal RH, . 1992. Herbicide residue distributions in relation to soil morphology in two California vertisols. Soil Sci 153(2):115–121.
Green LM. 1991. A cohort mortality study of forestry workers exposed to phenoxy acid herbicides. Br J Ind Med 48(4):234–238.2025588
Griffin RJ, Godfrey VB, Kim YC, . 1997a. Sex-dependent differences in the disposition of 2,4-dichlorophenoxyacetic acid in Sprague-Dawley rats, B6C3F1 mice, and Syrian hamsters. Drug Metab Dispos 25(9):1065–1071.9311622
Griffin RJ, Salemme J, Clark J, . 1997b. Biliary elimination of oral 2,4-dichlorophenoxyacetic acid and its metabolites in male and female Sprague-Dawley rats, B6C3F1 mice, and Syrian hamsters. J Toxicol Environ Health 51(4):401–413. 10.1080/00984109708984033.9202719
Grissom REJ, Brownie C, Guthrie FE. 1985. Dermal absorption of pesticides in mice. Pestic Biochem Physiol 24(1):119–123.
Hancock DB, Martin ER, Mayhew GM, . 2008. Pesticide exposure and risk of Parkinson’s disease: A family-based case-control study. BMC Neurol 10.1186/1471-2377-8-6.
Hansen WH, Quaife ML, Habermann RT, . 1971. Chronic toxicity of 2,4-dichlorophenoxyacetic acid in rats and dogs. Toxicol Appl Pharmacol 20(1):122–129.5110820
Haque R, Deagen J, Schmedding D. 1975. Binding of 2,4-dichloro- and 2,4,5-trichlorophenoxyacetic acids to bovine serum albumin. A proton magnetic resonance study. J Agric Food Chem 23(4):763–766.237953
Hardell L, Eriksson M. 1999. A case-control study of non-Hodgkin’s lymphoma and exposure to pesticides. Cancer Metastasis Rev 85(6):1353–1360.
Hardell L, Eriksson M, Degerman A. 1994. Exposure to phenoxyacetic acids, chlorophenols, or organic solvents in relation to histopathology, stage, and anatomical localization of non-Hodgkin’s lymphoma. Cancer Res 54(9):2386–2389.8162585
Harris SA, Solomon KR. 1992. Percutaneous penetration of 2,4-dichlorophenoxyacetic acid and 2,4-D dimethylamine salt in human volunteers. J Toxicol Environ Health 36(3):233–240. 10.1080/15287399209531634.1629934
Harris SA, Solomon KR, Stephenson GR. 1992. Exposure of homeowners and bystanders to 2,4-dichlorophenoxyacetic acid (2,4-D). J Environ Sci Health B 27(1):23–38. 10.1080/03601239209372765.1556388
Hartge P, Colt JS, Severson RK, . 2005. Residential herbicide use and risk of non-Hodgkin lymphoma. Cancer Epidemiol Biomarkers Prev 14(4):934–937. 10.1158/1055-9965.epi-04-0730.15824166
Hayes HM, Tarone RE, Cantor KP. 1995. On the association between canine malignant lymphoma and opportunity for exposure to 2,4-dichlorophenoxyacetic acid. Environ Res 70(2):119–125. 10.1006/enrs.1995.1056.8674480
Hayes HM, Tarone RE, Cantor KP, . 1991. Case-control study of canine malignant lymphoma: Positive association with dog owner’s use of 2,4-dichlorophenoxyacetic acid herbicides. J Natl Cancer Inst 83(17):1226–1231.1870148
Hays SM, Aylward LL, Driver J, . 2012. 2,4-D exposure and risk assessment: comparison of external dose and biomonitoring based approaches. Regul Toxicol Pharmacol 64(3):481–489. 10.1016/j.yrtph.2012.09.001.23017741
Health Canada. 2010. Phenoxy herbicide. Report on human biomonitoring of environmental chemicals in Canada. 198–201. http://www.hc-sc.gc.ca/ewh-semt/pubs/contaminants/chms-ecms/section8-eng.php#n8_8. August 28, 2015.
Hietanen E, Linnainmaa K, Vainio H. 1983. Effects of phenoxyherbicides and glyphosate on the hepatic and intestinal biotransformation activities in the rat. Acta Pharmacol Toxicol (Copenh) 53(2):103–112.6624478
Hill EV, Carlisle H. 1947. Toxicity of 2,4 dichlorophenoxyacetic acid for experimental animals. J Ind Hyg Toxicol 29(2):85–95.20286769
Hill RH, To T, Holler JS, . 1989. Residues of chlorinated phenols and phenoxy acid herbicides in the urine of Arkansas children. Arch Environ Contam Toxicol 18(4):469–474.2774664
Hill RH, Jr., Head SL, Baker S, . 1995. Pesticide residues in urine of adults living in the United States: Reference range concentrations. Environ Res 71(2):99–108. 10.1006/enrs.1995.1071.8977618
Hoar SK, Blair A, Holmes FF, . 1985. Herbicides and colon cancer. The Lancet 325(8440):1277–1278. 10.1016/s0140-6736(85)92349-9.
Hoar SK, Blair A, Holmes FF, . 1986. Agricultural herbicide use and risk of lymphoma and soft-tissue sarcoma. J Am Med Assoc 256(9):1141–1147.
Holland NT, Duramad P, Rothman N, . 2002. Micronucleus frequency and proliferation in human lymphocytes after exposure to herbicide 2,4-dichlorophenoxyacetic acid in vitro and in vivo. Mutat Res 521(1–2):165–178.12438013
Holman RE, Leidy RB, Walker AE. 2000. Evaluation of selected pesticides in North Carolina surface water supplies: Intake study. J Am Water Resour Assoc 36(1):75–85.
Hope BK, Pillsbury L, Boling B. 2012. A state-wide survey in Oregon (USA) of trace metals and organic chemicals in municipal effluent. Sci Total Environ 417–418:263–272. 10.1016/j.scitotenv.2011.12.028.
Hoppin JA, Umbach DM, London SJ, . 2006a. Pesticides and adult respiratory outcomes in the agricultural health study. Ann N Y Acad Sci 1076:343–354.17119214
Hoppin JA, Umbach DM, London SJ, . 2006b. Pesticides associated with wheeze among commercial pesticide applicators in the Agricultural Health Study. Am J Epidemiol 163(12):1129–1137.16611668
Hoppin JA, Umbach DM, London SJ, . 2008. Pesticides and atopic and nonatopic asthma among farm women in the Agricultural Health Study. Am J Respir Crit Care Med 177:11–18.17932376
Hoppin JA, Umbach DM, Long S, . 2017. Pesticides are associated with allergic and non-allergic wheeze among male farmers. Environ Health Perspect 125(4):535–543. 10.1289/ehp315.27384423
Hou L, Andreotti G, Baccarelli AA, . 2013. Lifetime pesticide use and telomere shortening among male pesticide applicators in the Agricultural Health Study. Environ Health Perspect 121(8):919–924. 10.1289/ehp.1206432.23774483
HSDB. 2015. 2,4-D. CASRN: 94-75-7. Hazardous Substances Data Bank. U.S. National Library of Medicine. http://toxnet.nlm.nih.gov. September 21, 2015.
IARC. 2018. 2,4-Dichlorophenoxyacetic acid. In: 2,4-Dichlorophenoxyacetic acid (2,4-D) and some organochlorine insecticides. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 113. Lyon, France: International Agency for Research on Cancer, 373–498. http://monographs.iarc.fr/ENG/Monographs/vol113/mono113-03.pdf. December 8, 2016.
IRIS. 2002. 2,4-Dichlorophenoxyacetic acid (2,4-D) (CASRN 94-75-7). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0150.htm. July 23, 2015.
Johnson WG, Lavy TL, Gbur EE. 1995. Sorption, mobility and degradation of triclopyr and 2,4-D on four soils. Weed Sci 43:678–684.
Joshi SC, Tibrewal P, Sharma A, . 2012. Evaluation of toxic effect of 2,4-D (2,4-dichlorophenoxyacetic acid) on fertility and biochemical parameters of male reproductive system of albino rats. Int J Pharm Sci 4(Suppl 3):338–342.
Kaioumova DF, Khabutdinova L. 1998. Cytogenetic characteristics of herbicide production workers in Ufa. Chemosphere 37(9–12):1755–1759.9828303
Kaneene JB, Miller R. 1999. Re-analysis of 2,4-D use and the occurrence of canine malignant lymphoma. Vet Hum Toxicol 41(3):164–170.10349709
Kavlock RJ, Short Rd JR, Chernoff N. 1987. Further evaluation of an in vivo teratology screen. Teratog Carcinog Mutagen 7:7–16.2884745
Kaya B, Yanikoglu A, Marcos R. 1999. Genotoxicity studies on the phenoxyacetates 2,4-D and 4-CPA in the Drosophila wing spot test. Teratog Carcinog Mutagen 19(4):305–312.10406894
Keller T, Skopp G, Wu M, . 1994. Fatal overdose of 2,4-dichlorphenoxyacetic acid (2,4-D). Forensic Sci Int 65(1):13–18.8206450
Khanna S, Fang SC. 1966. Metabolism of C14-labeled 2,4-dichlorophenoxyacetic acid in rats. J Agric Food Chem 14(5):500–503.
Kim CS, O’Tuama LA. 1981. Choroid plexus transport of 2,4-dichlorophenoxyacetic acid: Interaction with the organic acid carrier. Brain Res 224(1):209–212.7284837
Kim CS, Keizer RF, Pritchard JB. 1988. 2,4-Dichlorophenoxyacetic acid intoxication increases its accumulation within the brain. Brain Res 440(2):216–226.3359212
Kim CS, Gargas ML, Andersen ME. 1994. Pharmacokinetic modeling of 2,4-dichlorophenoxyacetic acid (2,4-D) in rat and in rabbit brain following single dose administration. Toxicol Lett 74(3):189–201.7871543
Kim CS, Binienda Z, Sandberg JA. 1996. Construction of a physiologically based pharmacokinetic model for 2,4-dichlorophenoxyacetic acid dosimetry in the developing rabbit brain. Toxicol Appl Pharmacol 136(2):250–259. 10.1006/taap.1996.0032.8619233
Kim CS, O’Tuama LA, Mann JD, . 1983. Saturable accumulation of the anionic herbicide, 2,4-dichlorophenoxyacetic acid (2,4-D), by rabbit choroid plexus: Early developmental origin and interaction with salicylates. J Pharmacol Exp Ther 225(3):699–704.6864528
Kim CS, Slikker W, Binienda Z, . 1995. Development of a physiologically based pharmacokinetic model for 2,4-dichlorophenoxyacetic acid dosimetry in discrete areas of the rabbit brain. Neurotoxicol Teratol 17(2):111–120.7760772
Kim CS, Sandberg JA, Slikker W, . 2001. Quantitative exposure assessment: Application of physiologically-based pharmacokinetic (PBPK) modeling of low-dose, long-term exposures of organic acid toxicant in the brain. Environ Toxicol Pharmacol 9(4):153–160.11292578
Kimura T, Kuroki K, Doi K. 1998. Dermatotoxicity of agricultural chemicals in the dorsal skin of hairless dogs. Toxicol Pathol 26(3):442–447.9608651
Kirrane EF, Hoppin JA, Kamel F, . 2005. Retinal degeneration and other eye disorders in wives of farmer pesticide applicators enrolled in the Agricultural Health Study. Am J Epidemiol 161:1020–1029.15901622
Kitchin KT, Brown JL. 1988. Biochemical effects of three chlorinated phenols in rat liver. Toxicol Environ Chem 16(3):165–172.
Klecka G, Persoon C, Currie RS. 2010. Chemicals of emerging concern in the Great Lakes Basin: An analysis of environmental exposures. Rev Environ Contam Toxicol 207:1–85.20652664
Klucinski P, Kossmann S, Tustanowski J, . 2001. Humoral and cellular immunity rates in chemical plant workers producing dust pesticides. Med Sci Monit 7(6):1270–1274.11687741
Knopp D. 1994. Assessment of exposure to 2,4-dichlorophenoxyacetic acid in the chemical industry: Results of a five year biological monitoring study. Occup Environ Med 51(3):152–159.8130842
Knopp D, Schiller F. 1992. Oral and dermal application of 2,4-dichlorophenoxyacetic acid sodium and dimethylamine salts to male rats: Investigations on absorption and excretion as well as induction of hepatic mixed-function oxidase activities. Arch Toxicol 66(3):170–174.1497479
Kogevinas M, Kauppinen T, Winkelmann R, . 1995. Soft tissue sarcoma and non-Hodgkin’s lymphoma in workers exposed to phenoxy herbicides, chlorophenols, and dioxins: Two nested case-control studies. Epidemiology 6(4):396–402.7548348
Kogevinas M, Becher H, Benn T, . 1997. Cancer mortality in workers exposed to phenoxy herbicides, chlorophenols, and dioxins. Am J Epidemiol 145(12):1061–1075.9199536
Kohli JD, Khanna RN, Gupta BM, . 1974. Absorption and excretion of 2,4-dichlorophenoxyacetic acid in man. Xenobiotica 2:97–100.
Kolberg J, Helgeland K, Jonsen J. 1973. Binding of 2,4-dichloro- and 2,4,5-trichlorophenoxyacetic acid to bovine serum albumin. Acta Pharmacol Toxicol (Copenh) 33(5):470–475.4801089
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992-1996. Ground Water 38(6):858–863.
Konasewich DE, Traversy WJ, Zar H. 1978. Great Lakes Water Quality Board-Appendix E. Status report on organic and heavy metal contaminants in the Lakes Erie, Michigan, Huron and Superior basins. Great Lakes Water Quality Board.
Konjuh C, Garcia G, Lopez L, . 2008. Neonatal hypomyelination by the herbicide 2,4-dichlorophenoxyacetic acid. Chemical and ultrastructural studies in rats. Toxicol Sci 104(2):332–340. 10.1093/toxsci/kfn085.18460445
Korte C, Jalal SM. 1982. 2,4-D induced clastogenicity and elevated rates of sister chromatid exchanges in cultured human lymphocytes. J Hered 73(3):224–226.7096985
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Ulsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554. 10.1248/jhs.48.545.
Kuntz DJ, Rao NGS, Berg IE, . 1990. Toxicity of mixtures of parathion, toxaphene and/or 2,4-D in mice. J Appl Toxicol 10(4):257–266.2391407
LaVerda NL, Goldsmith DF, Alavanja MCR, . 2015. Pesticide exposures and body mass index (BMI) of pesticide applicators from the Agricultural Health Study. J Toxicol Environ Health 78(20):1255–1276.
Lavy TL, Norris LA, Mattice JD, . 1987. Exposure of forestry ground workers to 2 4-D picloram and dichlorprop. Environ Toxicol Chem 6(3):209–224.
Lebov JF, Engel LS, Richardson D, . 2015. Pesticide exposure and end-stage renal disease risk among wives of pesticide applicators in the Agricultural Health Study. Environ Res 143(Pt A):198–210. 10.1016/j.envres.2015.10.002.26505650
Lee W, Lijinsky W, Heineman E, . 2004a. Agricultural pesticide use and adenocarcinomas of the stomach and oesophagus. Occup Environ Med 61(9):743–749. 10.1136/oem.2003.011858.15317914
Lee WJ, Cantor KP, Berzofsky JA, . 2004b. Non-Hodgkin’s lymphoma among asthmatics exposed to pesticides. Int J Cancer 111(2):298–302.15197786
Lee WJ, Sandler DP, Blair A, . 2007. Pesticide use and colorectal cancer risk in the Agricultural Health Study. Int J Cancer 121(2):339–346. 10.1002/ijc.22635.17390374
Lerda D, Rizzi R. 1991. Study of reproductive function in persons occupationally exposed to 2,4-dichlorophenoxyacetic acid (2,4-D). Mutat Res 262(1):47–50.1986284
Lerro CC, Beane Freeman LE, Portengen L, . 2017. A longitudinal study of atrazine and 2,4-D exposure and oxidative stress markers among Iowa corn farmers. Environ Mol Mutagen 58(1):30–38. 10.1002/em.22069.28116766
Lindquist NG, Ullberg S. 1971. Distribution of the herbicides 2,4,5-T and 2,4,-D in pregnant mice. Accumulation in the yolk sac epithelium. Experientia 27(12):1439–1441.5144855
Linnainmaa K. 1984. Induction of sister chromatid exchanges by the peroxisome proliferators 2,4-D, MCPA, and clofibrate in vivo and in vitro. Carcinogenesis 5(6):703–707.6722984
Liu D, Strachan WMJ, Thomson K, . 1981. Determination of the biodegradability of organic compounds. Environ Sci Technol 15(7):788–793.
Loomis D, Guyton K, Grosse Y, . 2015. Carcinogenicity of lindane, DDT, and 2,4-dichlorophenoxyacetic acid. Lancet Oncol 16(8):891–892. 10.1016/S1470-2045(15)00081-9.26111929
Madrigal-Bujaidar E, Hernandez-Ceruelos A, Chamorro G. 2001. Induction of sister chromatid exchanges by 2,4-dichlorophenoxyacetic acid in somatic and germ cells of mice exposed in vivo. Food Chem Toxicol 39(9):941–946.11498271
Mage DT, Allen RH, Gondy G, . 2004. Estimating pesticide dose from urinary pesticide concentration data by creatinine correction in the Third National Health and Nutrition Examination Survey (NHANES-III). J Expo Anal Environ Epidemiol 14:457–465.15367927
Magnusson J, Ramel C, Eriksson A. 1977. Mutagenic effects of chlorinated phenoxyacetic acids in Drosophila melanogaster. Hereditas 87(1):121–123.
Maire MA, Rast C, Landkocz Y, . 2007. 2,4-Dichlorophenoxyacetic acid: Effects on Syrian hamster embryo (SHE) cell transformation, c-Myc expression, DNA damage and apoptosis. Mutat Res 631(2):124–136. 10.1016/j.mrgentox.2007.03.008.17540612
Marouani N, Tebourbi O, Cherif D, . 2017. Effects of oral administration of 2,4-dichlorophenoxyacetic acid (2,4-D) on reproductive parameters in male Wistar rats. Environ Sci Pollut Res Int 24(1):519–526. 10.1007/s11356-016-7656-3.27734311
Marty MS, Neal BH, Zablotny CL, . 2013. An F1-extended one-generation reproductive toxicity study in Crl:CD(SD) rats with 2,4-dichlorophenoxyacetic acid. Toxicol Sci 136(2):527–547. 10.1093/toxsci/kft213.24072463
Mattsson JL, Charles JM, Yano BL, . 1997. Single-dose and chronic dietary neurotoxicity screening studies on 2,4-dichlorophenoxyacetic acid in rats. Fundam Appl Toxicol 40(1):111–119.9398493
Mazhar FM, Moawad KM, El-Dakdoky MH, . 2014. Fetotoxicity of 2,4-dichlorophenoxyacetic acid in rats and the protective role of vitamin E. Toxicol Ind Health 30(5):480–488. 10.1177/0748233712459915.22949405
McDuffie HH, Pahwa P, McLaughlin JR, . 2001. Non-Hodgkin’s lymphoma and specific pesticide exposures in men: Cross-Canada study of pesticides and health. Cancer Epidemiol Biomarkers Prev 10(11):1155–1163.11700263
Meister RT, Sine C, Gill-Totten JA, . 2014. 2,4-D. In: Crop protection handbook. Volume 100. Willoughby, OH: Meister Media Worldwide, 223–224.
Mersch-Sundermann V, Schneider U, Klopman G, . 1994. SOS induction in Escherichia coli and Salmonella mutagenicity: A comparison using 330 compounds. Mutagenesis 9(3):205–224.7934961
Metayer C, Colt JS, Buffler PA, . 2013. Exposure to herbicides in house dust and risk of childhood acute lymphoblastic leukemia. J Expo Sci Environ Epidemiol 23(4):363–370. 10.1038/jes.2012.115.23321862
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Mikalsen SO, Holen I, Sanner T. 1990. Morphological transformation and catalase activity of Syrian hamster embryo cells treated with hepatic peroxisome proliferators, TPA and nickel sulphate. Cell Biol Toxicol 6(1):1–13.2334865
Miles CJ, Pfeuffer RJ. 1997. Pesticides in canals of south Florida. Arch Environ Contam Toxicol 32:337–345.9175497
Miligi L, Costantini AS, Veraldi A, . 2006. Cancer and pesticides: An overview and some results of the Italian multicenter case-control study on hematolymphopoietic malignancies. Ann N Y Acad Sci 1076:366–377. 10.1196/annals.1371.036.17119216
Mills PK, Yang R. 2005. Breast cancer risk in Hispanic agricultural workers in California. Int J Occup Environ Health 11(2):123–131. 10.1179/oeh.2005.11.2.123.15875887
Mills PK, Yang RC. 2007. Agricultural exposures and gastric cancer risk in Hispanic farm workers in California. Environ Res 104(2):282–289. 10.1016/j.envres.2006.11.008.17196584
Mills PK, Yang R, Riordan D. 2005. Lymphohematopoietic cancers in the United Farm Workers of America (UFW), 1988-2001. Cancer Causes Control 16(7):823–830. 10.1007/s10552-005-2703-2.16132792
Moody RP, Nadeau B, Chu I. 1994. In vitro dermal absorption of pesticides: V. In vivo and in vitro comparison of the herbicide 2,4-dichlorophenoxyacetic acid in rat, guinea pig, pig, human and tissue-cultured skin. Toxicol in Vitro 8(6):1219–1224.20693091
Moody RP, Franklin CA, Ritter L, . 1990. Dermal absorption of the phenoxy herbicides 2,4-D, 2,4-D amine, 2,4-D isooctyl, and 2,4,5-T in rabbits, rats, rhesus monkeys, and humans: A cross-species comparison. J Toxicol Environ Health 29(3):237–245. 10.1080/15287399009531387.2313737
Morgan MK. 2015. Predictors of urinary levels of 2,4-dichlorophenoxyacetic acid, 3,5,6-trichloro-2-pyridinol, 3-phenoxybenzoic acid, and pentachlorophenol in 121 adults in Ohio. Int J Hyg Environ Health 218(5):479–488.25891895
Morgan MK, Wilson NK, Chuang JC. 2014. Exposures of 129 preschool children to organochlorines, organophosphates, pyrethroids, and acid herbicides at their homes and daycares in North Carolina. Int J Environ Res Public Health 11(4):3743–3764. 10.3390/ijerph110403743.24705361
Morgan MK, Sheldon LS, Thomas KW, . 2008. Adult and children’s exposure to 2,4-D from multiple sources and pathways. J Expo Sci Environ Epidemiol 18(5):486–494. 10.1038/sj.jes.7500641.18167507
Morris PC. 1990. Biotechnology and plant protection. FAO Plant Prot Bull 38(1):25–38.
Mustonen R, Kangas J, Vuojolahti P, . 1986. Effects of phenoxyacetic acids on the induction of chromosome aberrations in vitro and in vivo. Mutagenesis 1(4):241–245.3331666
Mustonen R, Elovaara E, Zitting A, . 1989. Effects of commercial chlorophenolate, 2,3,7,8-TCDD, and pure phenoxyacetic acids on hepatic peroxisome proliferation, xenobiotic metabolism and sister chromatid exchange in the rat. Arch Toxicol 63(3):203–208.2764706
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Neal BH, Bus J, Marty MS, . 2017. Weight-of-the-evidence evaluation of 2,4-D potential for interactions with the estrogen, androgen and thyroid pathways and steroidogenesis. Crit Rev Toxicol 47(5):352–408. 10.1080/10408444.2016.1272094.
Nesbitt HJ, Watson JR. 1980. Degradation of the herbicide 2,4-D in river water - II. The role of suspended sediment, nutrients and water temperature. Water Res 14:1689–1694.
Nielsen K, Kaempe B, Jensen-Holm J. 1965. Fatal poisoning in man by 24-dichlorophenoxyacetic acid (2,4-d): Determination of the agent in forensic materials. Acta Pharmacol Toxicol (Copenh) 22:224–234.14328196
NIH. 2014. Agricultural Health Study. National Institute of Health http://aghealth.nih.gov/. August 25, 2014.
NIOSH. 1994. Method 5001. Issue 2. 2,4-D. NIOSH manual of analytical methods (NMAM). Fourth Edition. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/500124-d.pdf. October 1, 2015.
NIOSH. 2016. NIOSH pocket guide to chemical hazards: 2,4-D. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0173.html. May 16, 2019.
Nishioka MG, Lewis RG, Brinkman MC, . 2001. Distribution of 2,4-D in air and on surfaces inside residences after lawn applications: Comparing exposure estimates from various media for young children. Environ Health Perspect 109(11):1185–1191.11713005
NITE. 2010a. Substance Data. #32: Bioaccumulation: Aquatic/sediment. 2,4-Dichlorophenoxyacetic acid. JCHECK - Japan Chemical Collaborative Knowledge database. Japanese National Institute of Technology and Evaluation. http://www.safe.nite.go.jp/jcheck/template.action?ano=22533&mno=3-927&cno=94-75-7&request_locale=en. June 22, 2015.
NITE. 2010b. Substance data. #28: Biodegradation in water: Screening tests. (2,4-Dichlorophenoxy)acetic acid. JCHECK - Japan Chemicals Collaborative Knowledge database. Japanese National Institute of Technology and Evaluation. http://www.safe.nite.go.jp/jcheck/template.action?ano=1603&mno=3-927&cno=94-75-7&request_locale=en. June 22, 2015.
Norris LA, Greiner D. 1967. The degradation of 2,4-D in forest litter. Bull Environ Contam Toxicol 2(2):65–74. 10.1007/bf01684146.24189689
NPIC. 2008. 2,4-D Technical fact sheet. National Pesticide Information Center. http://npic.orst.edu/factsheets/2,4-DTech.pdf. September 11, 2015.
NTP. 2014. Report on carcinogens. Thirteenth edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/pubhealth/roc/roc13/. April 9, 2015.
NTP. 2016. 14th Report on carcinogens. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. May 16, 2019.
Orberg J. 1980. Observations on the 2,4-dichlorophenoxyacetic acid (2,4-D) excretion in the goat. Acta Pharmacol Toxicol (Copenh) 46(1):78–80.7361563
OSHA. 2018a. 29CFR1910.1000: Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants Code of Federal Regulations. 29 CFR 1910.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 1, 2018.
OSHA. 2018b. 29CFR1915.1000: Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. 29 CFR 1915.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. 29CFR1926.55: Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
Osterloh J, Lotti M, Pond SM. 1983. Toxicologic studies in a fatal overdose of 2,4-D, MCPP, and chlorpyrifos. J Anal Toxicol 7(3):125–129.6193335
Ou LT. 1984. 2,4-D degradation and 2,4-D degrading microorganisms in soils. Soil Sci 137(2):100–107.
Ozaki K, Mahler JF, Haseman JK, . 2001. Unique renal tubule changes induced in rats and mice by the peroxisome proliferators 2,4-dichlorophenoxyacetic acid (2,4-D) and WY-14643. Toxicol Pathol 29(4):440–450.11560249
Pahwa P, McDuffie HH, Dosman JA, . 2006. Hodgkin lymphoma, multiple myeloma, soft tissue sarcomas, insect repellents, and phenoxyherbicides. J Occup Environ Med 48(3):264–274. 10.1097/01.jom.0000183539.20100.06.16531830
Panuwet P, Ladva C, Barr DB, . 2018. Investigation of associations between exposures to pesticides and testosterone levels in Thai farmers. Arch Environ Occup Health 73(4):205–218. 10.1080/19338244.2017.1378606.28901838
Patterson TA, Slikker W, Binienda Z, . 2000. Distribution of 2,4-dichlorophenoxyacetic acid (2,4-D) in the rat after low-dose, chronic administration. Toxicologist 54(1):56.
Pochettino AA, Hapon MB, Biolatto SM, . 2016. Effects of 2,4-dichlorophenoxyacetic acid on the ventral prostate of rats during the peri-pubertal, pubertal and adult stage. Drug Chem Toxicol 39(4):392–399. 10.3109/01480545.2015.1130718.26759115
Pont AR, Charron AR, Brand RM. 2004. Active ingredients in sunscreens act as topical penetration enhancers for the herbicide 2,4-dichlorophenoxyacetic acid. Toxicol Appl Pharmacol 195(3):348–354. 10.1016/j.taap.2003.09.021.15020197
Poulin P, Krishnan K. 1995. An algorithm for predicting tissue: Blood partition coefficients of organic chemicals from n-octanol: Water partition coefficient data. J Toxicol Environ Health 46(1):117–129. 10.1080/15287399509532021.7666490
Pritchard JB. 1980. Accumulation of anionic pesticides by rabbit choroid plexus in vitro. J Pharmacol Exp Ther 212:354–359.7351648
Que Hee SS, Sutherland RG, Vetter M. 1975. GLC analysis of 2,4-D concentrations in air samples from central Saskatchewan in 1972. Environ Sci Technol 9(1):62–66.
Rasmuson B, Svahlin H. 1978. Mutagenicity tests of 2,4-dichlorophenoxyacetic acid and 2,4,5-trichlorophenoxyacetic acid in genetically stable and unstable strains of Drosophila melanogaster. Ecol Bull 27:190–192.
RePORTER. 2018. 2,4-Dichlorophenoxyacetic acid. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. May 9, 2019.
Reynolds PM, Reif JS, Ramsdell HS, . 1994. Canine exposure to herbicide-treated lawns and urinary excretion of 2,4-dichlorophenoxyacetic acid. Cancer Epidemiol Biomarkers Prev 3(3):233–237.8019373
Riihimaki V, Asp S, Hernberg S. 1982. Mortality of 2,4-dichlorophenoxyacetic acid and 2,4,5-trichlorophenoxyacetic acid herbicide applicators in Finland: First report of an ongoing prospective cohort study. Scand J Work Environ Health 8(1):37–42.7134921
Rodgers CA, Stalling DL. 1972. Dynamics of an ester of 2,4-D in organs of three fish species. Weed Sci 20(1):101–105.
Rogers WM, Kendall DC, Salmon GD, . 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J AOAC Int 78(3):614–631.7756874
Rosenberg A, Alexander M. 1980. 2,4,5-Trichlorophenoxyacetic acid (2,4,5-T) decomposition in tropical soil and its cometabolism by bacteria in vitro. J Agric Food Chem 28(4):705–709.
Ross JH, Driver JH, Harris SA, . 2005. Dermal absorption of 2,4-D: A review of species differences. Regul Toxicol Pharmacol 41(1):82–91. 10.1016/j.yrtph.2004.10.001.15649830
Rosso SB, Di Paolo OA, Evangelista de Duffard AM, . 1997. Effects of 2,4-dichlorophenoxyacetic acid on central nervous system of developmental rats. Associated changes in ganglioside pattern. Brain Res 769(1):163–167.9374285
Rosso SB, Gonzalez M, Bagatolli LA, . 1998. Evidence of a strong interaction of 2,4-dichlorophenoxyacetic acid herbicide with human serum albumin. Life Sci 63(26):2343–2351.9877224
Rosso SB, Garcia GB, Madariaga MJ, . 2000a. 2,4-Dichlorophenoxyacetic acid in developing rats alters behaviour, myelination and regions brain gangliosides pattern. Neurotoxicology 21(1–2):155–163.10794395
Rosso SB, Caceres AO, de Duffard AM, . 2000b. 2,4-Dichlorophenoxyacetic acid disrupts the cytoskeleton and disorganizes the Golgi apparatus of cultured neurons. Toxicol Sci 56(1):133–140.10869461
RTECS. 2009. Acetic acid, (2,4-dichlorophenoxy)- RTECS #: AG682500, Cas#:94-75-7. The Registry of Toxic Effects of Chemical Substances. http://www.cdc.gov/niosh-rtecs/AG682428.html. September 11, 2015.
Saghir SA, Marty MS, Zablotny CL, . 2013a. Life-stage-, sex-, and dose-dependent dietary toxicokinetics and relationship to toxicity of 2,4-dichlorophenoxyacetic acid (2,4-D) in rats: Implications for toxicity test dose selection, design, and interpretation. Toxicol Sci 136(2):294–307. 10.1093/toxsci/kft212.24105888
Saghir SA, Marty MS, Zablotny CL, . 2013b. Supplementary data: Life-stage-, sex-, and dosedependent dietary toxicokinetics and relationship to toxicity of 2,4-dichlorophenoxyacetic acid (2,4-D) in rats: Implications for toxicity test dose selection, design, and interpretation. Toxicol Sci 136. https://academic.oup.com/toxsci/article/136/2/294/1682156#supplementary-data.
Sandal S, Yilmaz B. 2011. Genotoxic effects of chlorpyrifos, cypermethrin, endosulfan and 2,4-D on human peripheral lymphocytes cultured from smokers and nonsmokers. Environ Toxicol 26(5):433–442. 10.1002/tox.20569.20196147
Sandberg JA, Duhart HM, Lipe G, . 1996. Distribution of 2,4-dichlorophenoxyacetic acid (2,4-D) in maternal and fetal rabbits. J Toxicol Environ Health 49(5):497–509.8968410
Saracci R, Kogevinas M, Bertazzi P, . 1991. Cancer mortality in workers exposed to chlorophenoxy herbicides and chlorophenols. Lancet 338(8774):1027–1032.1681353
Sathyanarayana S, Basso O, Karr CJ, . 2010. Maternal pesticide use and birth weight in the agricultural health study. J Agromedicine 15(2):127–136.20407994
Sauerhoff MW, Braun WH, Blau GE, . 1977. The fate of 2,4-dichlorophenoxyacetic acid (2,4-D) following oral administration to man. Toxicology 8(1):3–11.929615
Scher DP, Sawchuk RJ, Alexander BH, . 2008. Estimating absorbed dose of pesticides in a field setting using biomonitoring data and pharmacokinetic models. J Toxicol Environ Health A 71(6):373–383. 10.1080/15287390701801638.18246497
Schop RN, Hardy MH, Goldberg MT. 1990. Comparison of the activity of topically applied pesticides and the herbicide 2,4-D in two short-term in vivo assays of genotoxicity in the mouse. Fundam Appl Toxicol 15(4):666–675.2086312
Schreinemachers DM. 2010. Perturbation of lipids and glucose metabolism associated with previous 2,4-D exposure: a cross-sectional study of NHANES III data, 1988-1994. Environ Health 9:11. 10.1186/1476-069x-9-11.20187939
Schultz DP, Whitney EW. 1974. Monitoring 2,4-D residues at Loxahatchee National Wildlife Refuge. Pestic Monit J 7(3–4):146–152.
Schwetz BA, Sparschu G, Gehring PJ. 1971. The effect of 2,4-dichlorophenyoxyacetic acid (2,4-D) and esters of 2,4-D on rat embryonal, foetal and neonatal growth and development. Food Cosmet Toxicol 9(6):801–807.5144120
Slager RE, Poole JA, LeVan TD, . 2009. Rhinitis associated with pesticide exposure among commercial pesticide applicators in the Agricultural Health Study. Occup Environ Med 66(11):718–724. 10.1136/oem.2008.041798.19289390
Smith RA, Lewis D. 1987. Suicide by ingestion of 2,4-D: A case history demonstrating the prudence of using GC/MS as an investigative rather than a confirmatory tool. Vet Hum Toxicol 29(3):259–261.3604050
Smith AM, Smith MT, La Merrill MA, . 2017. 2,4-dichlorophenoxyacetic acid (2,4-D) and risk of non-Hodgkin lymphoma: a meta-analysis accounting for exposure levels. Ann Epidemiol 27(4):281–289. 10.1016/j.annepidem.2017.03.003.28476329
Soloneski S, Gonzalez NV, Reigosa MA, . 2007. Herbicide 2,4-dichlorophenoxyacetic acid (2,4-D)-induced cytogenetic damage in human lymphocytes in vitro in presence of erythrocytes. Cell Biol Int 31(11):1316–1322. 10.1016/j.cellbi.2007.05.003.17606385
Squibb RE, Tilson HA, Mitchell CL. 1983. Neurobehavioral assessment of 2,4-dichlorophenoxyacetic acid (2,4-D) in rats. Neurobehav Toxicol Teratol 5(3):331–335.6877474
Stanley CW, Barney JE, Helton MR, . 1971. Measurement of atmospheric levels of pesticides. Environ Sci Technol 5(5):430–435.
Steiss JE, Braund KG, Clark EG. 1987. Neuromuscular effects of acute 2 4-d exposure in dogs. J Neurol Sci 78(3):295–302.3585404
Sturtz N, Evangelista de Duffard A, Duffard R. 2000. Detection of 2,4-dichlorophenoxyacetic acid (2,4-D) residues in neonates fed by 2,4-D exposed dams. Neurotoxicology 21(1–2):147–154.10794394
Sturtz N, Bongiovanni B, Rassetto M, . 2006. Detection of 2,4-dichlorophenoxyacetic acid in rat milk of dams exposed during lactation and milk analysis of their major components. Food Chem Toxicol 44(1):8–16. 10.1016/j.fct.2005.03.012.16216402
Sturtz N, Deis RP, Jahn GA, . 2008. Effect of 2,4-dichlorophenoxyacetic acid on rat maternal behavior. Toxicology 247(2–3):73–79. 10.1016/j.tox.2008.02.001.18420331
Sturtz N, Jahn GA, Deis RP, . 2010. Effect of 2,4-dichlorophenoxyacetic acid on milk transfer to the litter and prolactin release in lactating rats. Toxicology 271(1–2):13–20. 10.1016/j.tox.2010.01.016.20122984
Styles JA. 1973. Cytotoxic effects of various pesticides in vivo and in vitro. Mutat Res 21(1):50–51.
Subba-Rao RV, Rubin HE, Alexander M. 1982. Kinetics and extent of mineralization of organic chemicals at trace levels in freshwater and sewage. Appl Environ Microbiol 43(5):1139–1150.16346011
Swan SH, Kruse RL, Liu F, . 2003. Semen quality in relation to biomarkers of pesticide exposure. Environ Health Perspect 111(12):1478–1484.12948887
Tanner CM, Ross GW, Jewell SA, . 2009. Occupation and risk of parkinsonism: A multicenter case-control study. Arch Neurol 66(9):1106–1113. 10.1001/archneurol.2009.195.19752299
Thomas KW, Dosemeci M, Coble JB, . 2010a. Assessment of a pesticide exposure intensity algorithm in the agricultural health study. J Expo Sci Environ Epidemiol 20(6):559–569. 10.1038/jes.2009.54.19888312
Thomas KW, Dosemeci M, Hoppin JA, . 2010b. Urinary biomarker, dermal, and air measurement results for 2,4-D and chlorpyrifos farm applicators in the Agricultural Health Study. J Expo Sci Environ Epidemiol 20(2):119–134. 10.1038/jes.2009.6.19240759
Thongsinthusak T, Ross JH, Saiz SG, . 1999. Estimation of dermal absorption using the exponential saturation model. Regul Toxicol Pharmacol 29:37–43.10051417
Thorn A, Gustavsson P, Sadigh J, . 2000. Mortality and cancer incidence among Swedish lumberjacks exposed to phenoxy herbicides. Occup Environ Med 57:718–720.10984346
Timchalk C. 2004. Comparative inter-species pharmacokinetics of phenoxyacetic acid herbicides and related organic acids. Evidence that the dog is not a relevant species for evaluation of human health risk. Toxicology 200(1):1–19. 10.1016/j.tox.2004.03.005.15158559
Torstensson L. 1978. Effects of phenoxyacetic acid herbicides on soil organisms. Ecol Bull 27:263–284.
Torstensson NTL, Stark J, Goeransson B. 1975. The effect of repeated applications of 2,4-D and MCPA on their breakdown in soil. Weed Res 15(3):159–164.
Tripathy NK, Routray PK, Sahu GP, . 1993. Genotoxicity of 2,4-dichlorophenoxyacetic acid tested in somatic and germ-line cells of Drosophila. Mutat Res 319(3):237–242.7694145
Troudi A, Ben Amara I, Samet AM, . 2012a. Oxidative stress induced by 2,4-phenoxyacetic acid in liver of female rats and their progeny: Biochemical and histopathological studies. Environ Toxicol 27(3):137–145. 10.1002/tox.20624.20607813
Troudi A, Sefi M, Ben Amara I, . 2012b. Oxidative damage in bone and erythrocytes of suckling rats exposed to 2,4-dichlorophenoxyacetic acid. Pestic Biochem Physiol 104(1):19–27.
Turkula TE, Jalal SM. 1985. Increased rates of sister chromatid exchanges induced by the herbicide 2,4-D. J Hered 76(3):213–214.3998443
Tyynela K, Elo HA, Ylitalo P. 1990. Distribution of three common chlorophenoxyacetic acid herbicides into the rat brain. Arch Toxicol 64(1):61–65.2306196
USDA. 2001. 2,4-D-Acid, CASRN: 94-75-7. ARS Pesticide properties database. U.S. Department of Agriculture. http://www.ars.usda.gov/util/download.cfm?file=SP2UserFiles/ad_hoc/12755100DatabaseFiles/PesticidePropertiesDatabase/IndividualPesticideFiles/2,4-D-ACID.TXT. September 11, 2015.
USDA. 2014. Pesticide data program. Annual summary, calendar year 2013. U.S. Department of Agriculture. http://www.ams.usda.gov/sites/default/files/media/2013%20PDP%20Anuual%20Summary.pdf. September 24, 2015.
USGS. 1987. Chlorophenoxy acids, total recoverable (0-3105-83) and dissolved (0-11-5-83), gas chromatographic. Techniques of water-resources investigations of the United States Geological Survey. Chapter A3. Methods for the determination of organic substances in water and fluvial sediments. U.S. Geological Survey. 40–43. http://pubs.usgs.gov/twri/twri5a3/pdf/twri_5-A3.pdf. September 11, 2015.
USGS. 2007. The quality of our nation’s waters. Pesticides in the nation’s streams and ground water, 1992-2001. U.S. Geological Survey. https://pubs.er.usgs.gov/publication/cir1291. May 10, 2019.
USGS. 2016. Pesticide National Synthesis Project. National Water-Quality Assessment Program. Estimated agricultural use for 2,4-D, 2014. (Preliminary). U.S. Geological Survey. http://water.usgs.gov/nawqa/pnsp/usage/maps/show_map.php?year=2014&map=24D&hilo=L&disp=2,4-D. October 6, 2016.
Valcin M, Henneberger PK, Kullman GJ, . 2007. Chronic bronchitis among nonsmoking farm women in the Agricultural Health Study. J Occup Environ Med 49:574–583.17495700
van Ravenzwaay B, Hardwick TD, Needham D, . 2003. Comparative metabolism of 2,4-dichlorophenoxyacetic acid (2,4-D) in rat and dog. Xenobiotica 33(8):805–821. 10.1080/0049825031000135405.12936702
Vasudevan D, Cooper EM. 2004. 2,4-D sorption in iron oxide-rich soils: Role of soil phosphate and exchangeable Al. Environ Sci Technol 38:163–170.14740732
Venkat JA, Shami S, Davis K, . 1995. Relative genotoxic activities of pesticides evaluated by a modified SOS microplate assay. Environ Mol Mutagen 25(1):67–76.7875128
Venkov P, Topashka-Ancheva M, Georgieva M, . 2000. Genotoxic effect of substituted phenoxyacetic acids. Arch Toxicol 74(9):560–566.11131037
Vogel E, Chandler JLR. 1974. Mutagenicity testing of cyclamate and some pesticides in Drosophila melanogaster. Experientia 6:621–623.
von Stackelberg K. 2013. A systematic review of carcinogenic outcomes and potential mechanisms from exposure to 2,4-D and MCPA in the environment. J Toxicol 2013:371610. 10.1155/2013/371610.23533401
Waite DT, Cessna AJ, Grover R, . 2002. Environmental concentrations of agricultural herbicides: 2,4-d and triallate. J Environ Qual 31(1):129–144.11837416
Wang Y, Subb-Rao RV, Alexander M. 1984. Effect of substrate concentration and organic and inorganic compounds on the occurrence and rate of mineralization and cometabolism. Appl Environ Microbiol 47(6):1195–1200.16346555
Watson JR. 1977. Seasonal variation in the biodegradation of 2,4-D in river water. Water Res 14:153–157.
Webber MD, Wang C. 1995. Industrial organic compounds in selected Canadian soils. Can J Soil Sci 75:513–524.
Weisenburger DD. 1990. Environmental epidemiology of non-Hodgkin’s lymphoma in eastern Nebraska. Am J Ind Med 18(3):303–305.2220835
Weselak M, Aruckle TE, Wigle DT, . 2007. In utero pesticide exposure and childhood morbidity. Environ Res 103(1):79–86.17084836
Weselak M, Arbuckle TE, Wigle DT, . 2008. Pre- and post-conception pesticide exposure and the risk of birth defects in an Ontario farm population. Reprod Toxicol 25(4):472–480.18586452
Wester RC, Melendres J, Logan F, . 1996. Percutaneous absorption of 2,4-dichlorophenoxyacetic acid from soil with respect to soil load and skin contact time: In vivo absorption in rhesus monkey and in vitro absorption in human skin. J Toxicol Environ Health 47(4):335–344.8600287
WHO. 1989. 2,4-Dichlorophenoxyacetic acid (2,4-D) - environmental aspects. Environmental Health Criteria 84. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc84.htm. September 11, 2015.
WHO. 2003. 2,4-D in drinking-water. Background document for development of WHO Guidelines for drinking-water quality. World Health Organization. WHO/SDE/WSH/03.04/70. http://www.who.int/water_sanitation_health/dwq/chemicals/24D.pdf. September 22, 2015.
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2017. Guidelines for drinking-water quality: fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. May 16, 2019.
Wilson RD, Geronimo J, Armbruster JA. 1997. 2,4-D Dissipation in field soils after applications of 2,4-D dimethylamine salt and 2,4-D 2-ethylhexyl ester. Environ Toxicol Chem 16(6):1239–1246.
Wojtalik TA, Hall TF, Hill LO. 1971. Monitoring ecological conditions associated with widescale applications of DMA 2,4-D to aquatic environments. Pestic Monit J 4(4):184–203.5090146
Woods JS, Polissar L, Severson RK, . 1987. Soft tissue sarcoma and non-Hodgkin’s lymphoma in relation to phenoxyherbicide and chlorinated phenol exposure in western Washington. J Natl Cancer Inst 78:899–910.3471999
Yang W, Carmichael SL, Roberts EM, . 2014. Residential agricultural pesticide exposures and risk of neural tube defects and orofacial clefts among offspring in the San Joaquin Valley of California. Am J Epidemiol 179(6):740–748. 10.1093/aje/kwt324.24553680
Yiin JH, Ruder AM, Stewart PA, . 2012. The Upper Midwest Health Study: A case-control study of pesticide applicators and risk of glioma. Environ Health 11:39. 10.1186/1476-069x-11-39.22691464
Yilmaz HR, Yuksel E. 2005. Effect of 2,4-dichlorophenoxyacetic acid on the activities of some metabolic enzymes for generating pyridine nucleotide pool of cells from mouse liver. Toxicol Ind Health 21(9):231–237.16342474
Ylitalo P, Narhi U, Elo HA. 1990. Increase in the acute toxicity and brain concentrations of chlorophenoxyacetic acids by probenecid in rats. Gen Pharmacol 21(5):811–814.2276599
Zahm SH. 1997. Mortality study of pesticide applicators and other employees of a lawn care service company. J Occup Environ Med 39(11):1055–1067.9383716
Zahm SH, Weisenburger DD, Babbit PA, . 1990. A case-control study of non-Hodgkin’s lymphoma and the herbicide 2,4-dichlorophenoxyacetic acid (2,4-D) in eastern Nebraska. Epidemiology 1(5):349–356.2078610
Zeljezic D, Garaj-Vrhovac V. 2004. Chromosomal aberrations, micronuclei and nuclear buds induced in human lymphocytes by 2,4-dichlorophenoxyacetic acid pesticide formulation. Toxicology 200(1):39–47. 10.1016/j.tox.2004.03.002.15158562
Zetterberg G. 1978. Genetic effects of phenoxy acids on microorganisms. Ecol Bull 27:193–204.
Zetterberg G, Busk L, Elovson R, . 1977. The influence of pH on the effects of 2,4-D (2,4-dichlorophenoxyacetic acid, Na salt) on Saccharomyces cerevisiae and Salmonella typhimurium. Mutat Res 42(1):3–18.15215