# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Obaid Faroon, D.V.M., Ph.D. (Lead)
  Hana R. Pohl, M.D., Ph.D.
  Rae T. Benedict, Ph.D.
  Robert Williams, Ph.D.
  ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA

- Fernando Llados, Ph.D.
  David W. Wohlers, Ph.D.
  Courtney Hard, B.A.
  Laura A. McIlroy, B.A.
  Gary Diamond, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute of Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.

## PEER REVIEWERS

1. Dr. Stephen M. Roberts, Director, Center for Environmental & Human Toxicology and Professor, College of Veterinary Medicine, College of Medicine, and College of Public Health and Health Professions, University of Florida, Gainesville, Florida
2. Dr. Ivan Rusyn, Department of Veterinary Integrative Biosciences, College of Veterinary Medicine & Biomedical Sciences, Texas A&M University, College Station, Texas
3. Dr. Ted W. Simon, DABT, Ted Simon LLC, Winston, GA
4. Dr. Lucio G. Costa, Department of Environmental and Occupational Health Sciences, University of Washington, Seattle, Washington
5. Dr. Aaron E. Blair, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland
6. Dr. Nancy K. Wilson, Wilson Associates, Chapel Hill, North Carolina

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.