# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 2,4-D in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 2,4-D.

Table 7-1 Regulations and Guidelines Applicable to 2,4-D

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2002
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018
EPA | 1-Day health advisory (10-kg child) | 1 mg/L | EPA 2018
EPA | 10-Day health advisory (10-kg child) | 0.3 mg/L | EPA 2018
EPA | DWEL | 0.2 mg/L | EPA 2018
EPA | Lifetime health advisory | No data | EPA 2018
EPA | 10^−4^ Cancer risk | No data | EPA 2018
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.07 mg/L | EPA 2009
EPA | PHG | 0.07 mg/L | EPA 2009
EPA | OPP’s RfD | 0.21 mg/kg/day | EPA 2017
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value | 0.03 mg/L^a^ | WHO 2017
WHO | ADI | 0–0.01 mg/kg body weight^b^ | WHO 2017
FDA | Substances added to food | Not listed^c^ | FDA 2018
FDA | Allowable level in bottled water | 0.07 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Group D^d^ | EPA 2005a
IARC | Carcinogenicity classification | Group 2B^e^ | IARC 2018
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | 10 mg/m^3^ | OSHA 2018a, OSHA 2018b, OSHA 2018c
NIOSH | REL (up to 10-hour TWA) | 10 mg/m^3^ | NIOSH 2016
NIOSH | IDLH | 100 mg/m^3^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016b
DOE | PACs-air | | DOE 2018b
DOE | PAC-1^f^ | 30 mg/m^3^ | DOE 2018b
DOE | PAC-2^f^ | 94 mg/m^3^ | DOE 2018b
DOE | PAC-3^f^ | 500 mg/m^3^ | DOE 2018b

a Applies to free acid.

b For the sum of 2,4-D and its salts and esters.

c The Substances Added to Food inventory (formerly EAFUS) contains food additives and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in foods prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food or as delisted color additives, and some substances “no longer FEMA GRAS.”

d Group D: not classifiable as to human carcinogenicity.

e Group 2B: possibly carcinogenic to humans

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018a).

ADI = acceptable daily intake; AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OPP = Office of Pesticide Programs; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; PHG = public health goal; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; T4 = thyroxine; TWA = time-weighted average; WHO = World Health Organization