# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

2,4-D is a free acid, phenoxy herbicide belonging to the phenoxyacetic acid chemical family, which is widely used in the United States. While the free acid is itself used as an herbicide, there are nine forms of 2,4-D registered as active ingredients in end use products. These include salts, amines, and esters of 2,4-D (EPA 2005a). Derivatives include the sodium salt, diethanolamine salt, dimethyl amine salt, isopropylamine salt, triisopropanolamine salt, butoxyethyl ester, ethylhexyl ester, and isopropyl ester. Almost 90–95% of total 2,4-D global use is accounted for by the dimethyl amine salt and ethylhexyl ester (Charles et al. 2001).

Formulations of 2,4-D and its derivatives vary in their chemical properties and behavior in the environment. However, most quantified analyses of 2,4-D and its derivatives are expressed in terms of the free acid (EPA 2005a).

Information regarding the chemical identity of 2,4-D and its derivatives are provided in Tables 4-1 and 4-2, respectively.

Table 4-1 Chemical Identity of 2,4-D^a^

Characteristic | Information
Chemical name | 2,4-Dichlorophenoxyacetic acid
Synonym(s) | 2,4-D; 2,4-D Acid; Acetic acid, (2,4-dichlorophenoxy)-
Registered trade name(s)^b^ | Aqua-Kleen; Citrus Fix; Pyresta; Cimarron; Restore; Rush 24; 240; AMINO; Amoxone; Chloroxone; Crop Rider; Dinoxol; Dormone; Emulsamine; Fernimine; Fernoxone; Gesapax-H; Rilof-H; Target; Arena; Campeon; Fenix; Fenix Gold; Stockton; Talion; Turuna; Valsamba; Valsamin; Barrage; Brush-Rhap; Double Up; EndRun; HardBall; Opti-Amine; Trump-Card; Unison; Broadrange; Foundation; Weco Max; Brash; Phenoxy 088; Rugged; Strike; Charge; Dacomin; Chaser; Clean amine; Colt; Crossbow; Rifle; Saber; Salvo; Savage; Shotgun; Whiteout; Defy; Dical; Harvade; Willomine; Duplosan; Dyvel; Lotus; Topshot; U 46; Weedmaster; Speed-Mix; Gen-Amin; Gen-Ester; Grotex Complex; Grox; Trago
Chemical formula | C_8_H_6_Cl_2_O_3_
Chemical structure | [image]
CAS Registry Number | 94-75-7

a All information obtained from HSDB (2015), unless otherwise noted.

b Meister et al. 2014.

2,4-D = 2,4-dichlorophenoxyacetic acid; CAS = Chemical Abstracts Services; HSDB = Hazardous Substance Data Bank

Table 4-2 Chemical Identity of 2,4-D Derivatives

Characteristic | Information^a^
Chemical name | 2,4-D Sodium^b^ | 2,4-D Diethanolamine^c^ | 2,4-D Dimethylamine
Synonym(s) | Acetic acid, (2,4-dichlorophenoxy)-, sodium salt; Sodium 2,4-dichlorophenoxyacetate; 2,4-Dichlorophenoxyacetic acid, sodium salt; 2,4-D Na^b^ | 2,4-Diolamine; Acetic acid, (2,4-dichlorophenoxy)-, diethanolamine salt; 2,4-D Bis(2-hydroxyethyl) ammonium; 2,4-D DEA^b,c^ | Acetic acid, (2,4-dichlorophenoxy)-, dimethylamine (1:1); (2,4-Dichlorophenoxy) acetic acid dimethylamine salt; Dimethylammonium (2,4-dichlorophenoxy) acetate; 2,4-D DMA
Registered trade name(s) | See 2,4-D in Table 4-1 | See 2,4-D in Table 4-1 | See 2,4-D in Table 4-1
Chemical formula | C_8_H_5_Cl_2_O_3_.Na^b^ | C_8_H_6_Cl_2_O_3_.C_4_H_11_NO_2_^b^ | C_8_H_6_Cl_2_O_3_.C_2_H_7_N
Chemical structure^c^ | [image] | [image] | [image]
CAS Registry Number | 2702-72-9 | 5742-19-8 | 2008-39-1
Chemical name | 2,4-D Isopropylamine^c^ | 2,4-D Triisopropanolamine^c^ | 2,4-D Butoxyethyl ester
Synonym(s) | 2,4-D-isopropylammonium; Acetic acid, (2,4-dichlorophenoxy)-, isopropylamine salt; 2-Propanamine, (2,4-dichlorophenoxy) acetate; 2,4-D IPA^b,c^ | Acetic acid, (2,4-dichlorophenoxy)-, triisopropanolamine salt; 2,4-D-tris(2-hydroxypropyl) ammonium; 2-Propanol, 1,1’,1”-nitrilotris-, (2,4-dichlorophenoxy) acetate; 2,4-D TIPA^b,c^ | Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester; 2,4-Dichlorophenoxyacetic acid, butoxyethyl ester; 2,4-D BEE
Registered trade name(s) | See 2,4-D in Table 4-1 | See 2,4-D in Table 4-1 | See 2,4-D in Table 4-1
Chemical formula | C_8_H_6_Cl_2_O_3_.C_3_H_9_N^b^ | C_8_H_6_Cl_2_O_3_.C_9_H_21_NO_3_^b^ | C_14_H_18_Cl_2_O_4_
Chemical structure^c^ | [image] | [image] | [image]
CAS Registry Number | 5742-17-6 | 32341-80-3 | 1929-73-3
Chemical name | 2,4-D Ethylhexyl ester | 2,4-D Isopropyl ester
Synonym(s) | Isooctyl(2-ethylhexyl) 2,4-dichlorophenoxyacetate; 2,4-D, 2-ethylhexyl; 2-Ethylhexyl (2,4-dichlorophenoxy) acetate; Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester; 2,4-D EHE | Acetic acid, (2,4-dichlorophenoxy)-, isopropyl ester; Acetic acid, (2,4-dichlorophenoxy)-, 1-methylethyl ester; 2,4-Dichlorophenoxyacetic acid isopropyl ester; Isopropyl (2,4-dichlorophenoxy)acetate; Isopropyl 2,4-D ester; 2,4-D IPE
Registered trade name(s) | See 2,4-D in Table 4-1 | See 2,4-D in Table 4-1
Chemical formula | C_16_H_22_Cl_2_O_3_ | C_11_H_12_Cl_2_O_3_
Chemical structure^c^ | [image] | [image]
CAS Registry Number | 1928-43-4 | 94-11-1

a All information obtained from HSDB (2015), unless otherwise noted.

b Meister et al. 2014.

c EPA 2005a.

2,4-D = 2,4-dichlorophenoxyacetic acid; CAS = Chemical Abstracts Services; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 2,4-D and its derivatives are provided in Tables 4-3 and 4-4, respectively.

Table 4-3 Physical and Chemical Properties of 2,4-D^a^

Property | Information
Molecular weight | 221.03
Color | White to yellow
Physical state | Crystalline powder
Melting point | 138°C
Boiling point | 160°C (at 4 mm Hg)
Density/specific gravity:
at 25°C | 1.42
Odor | Odorless; slightly phenolic
Odor threshold | 3.13 mg/kg
Solubility:
Water at 20°C | 540 mg/L
Water at 25°C | 677 mg/L
Organic solvents at 20°C:
Ethanol | 1,250 g/kg
Diethyl ether | 243 g/kg
Heptane | 1.1 g/kg
Toluene | 6.7 g/kg
Xylene | 5.8 g/kg
Octanol | 120 g/L (25°C)
Partition coefficients:
Log K_ow_ | 2.81
Log K_oc_ | 19.6–135.7
Vapor pressure at 20°C | 1.40×10^−7^ mm Hg
Henry’s law constant at 20°C | 9.75×10^−8^ atm-m^3^/mol
Autoignition temperature | No data
Flashpoint | Not combustible
Flammability limits | No data
Conversion factors | No data
Explosive limits | No data

a All information obtained from HSDB (2015).

2,4-D = 2,4-dichlorophenoxyacetic acid

Table 4-4 Physical and Chemical Properties of 2,4-D Derivatives^a^

Property | 2,4-D Sodium | 2,4-D Diethanolamine
Molecular weight | 243.03^b^ | 326.18^b^
Color | White^b^ | Cream^b^
Physical state | Powder^b^ | Powder^b^
Melting point | 200°C^c^ | 83°C^c^
Boiling point | No data | No data
Density:
at 25°C | 42.2 pounds/feet^3^ (0.676 g/cm^3^) (bulk)^c^ | 0.762 g/cm^3^ (bulk)^c^
Odor | No data | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25°C | 4.5×10^4^ mg/L (unbuffered solution)^b^ | 8.06×10^5^ mg/L (unbuffered solution)^b^
Organic solvents | No data | No data
Partition coefficients:
Log K_ow_ | Not applicable^b,d^ | 0.0224–1.65^b^
Log K_oc_ | No data | No data
Vapor pressure at 25°C | Not applicable^b,d^ | 9.98×10^−8^ mm Hg^b^
Henry’s law constant at 25°C | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

Property | 2,4-D Dimethylamine | 2,4-D Isopropylamine
Molecular weight | 266.1 | 280.04^b^
Color | White (pure); amber (technical)^b^ | Amber^b^
Physical state | Crystals (pure); aqueous liquid (technical)^b^ | Aqueous liquid^b^
Melting point | 85–87°C | 121°C^c^
Boiling point | Decomposition | No data
Density/specific gravity:
at 20°C | 1.23^c^ | 1.15^c^
Odor | Odorless | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25°C | 3.0×10^6^ g/mL (20°C) | 1.74×10^5^ g/mL (pH 5); 4.36×10^5^ g/mL (pH 7); 3.31×10^5^ g/mL (pH 9); (unbuffered solutions)^b^
Organic solvents | Soluble in methyl, ethyl, and isopropyl alcohols, and acetone; insoluble in kerosene and diesel oil | No data
Organic solvents at 20°C
Acetonitrile | 1.06 g/100 mL
Methanol | >50 g/100 mL
Toluene | 0.165 g/100 mL
n-Hexane | 0.00357 g/100 mL
Octanol | 5.41 g/100 mL
Partition coefficients:
Log K_ow_ | 0.65 | Not applicable^b,d^
Log K_oc_ | 1.85–2.13 | No data
Vapor pressure at 25°C | 1 ×10^−7^ mm Hg^b^ | Not applicable^b,d^
Henry’s law constant at 25°C | 1.4×10^−16^ atm-m^3^/mol^b^ | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | Not flammable | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

Property | 2,4-D Triisopropanolamine | 2,4-D Butoxyethyl ester
Molecular weight | 412.31^b^ | 321.2
Color | Amber^b^ | Amber; colorless
Physical state | Aqueous liquid^b^ | Liquid
Melting point | 87–110°C^c^ | <25°C
Boiling point | No data | 89°C^c^
Density/specific gravity:
at 20°C | 1.21 | 1.232 g/cm^3^
Odor | No data | Odorless (pure); fuel oil-like (technical)
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25°C | 4.61×10^5^ g/mL (pH 5); 4.61×10^5^ g/mL (pH 7); 1.04×10^5^ g/mL (pH 9); (unbuffered solutions)^b^ | 12 mg/L
Organic solvents | No data | Miscible in acetone, acetonitrile, n-hexane, and methanol; soluble in oils
Partition coefficients:
Log K_ow_ | Not applicable^b,d^ | 4.1^b^
Log K_oc_ | No data | No data
Vapor pressure at 25°C | Not applicable^b,d^ | 4.5×10^−6^ mm Hg
Henry’s law constant at 25°C | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | >79°C (open cup)
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

Property | 2,4-D Ethylhexyl ester | 2,4-D Isopropyl ester
Molecular weight | 333.28 | 263.12
Color | Golden yellow | Colorless
Physical state | Liquid | Liquid
Melting point | <−37°C | 5–25°C
Boiling point | >300°C (decomposition) | 240°C^c^
Density:
at 20°C | 1.148 | No data
at 25°C/25°C | No data | 1.255–1.270
Odor | Sweet, slightly pungent | Fuel oil-like (technical)
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25°C | 0.086 mg/L | 37.3 mg/L
Organic solvents | No data | Soluble in alcohols and most oils
Partition coefficients:
Log K_ow_ | 5.78 | 253.8^c^
Log K_oc_ | No data | 2.78^b^
Vapor pressure at 25°C | 3.6×10^−6^ mm Hg^b^ | 2.32×10^−4^ mm Hg
Henry’s law constant at 25°C | 1.8×10^−5^ atm-m^3^/mol | 2.2×10^−6^ atm-m^3^/mol^b^
Autoignition temperature | No data | No data
Flashpoint | 171°C (open cup) | >79°C (open cup)
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

a All information obtained from HSDB (2015), unless otherwise noted.

b NPIC 2008.

c EPA 2005a.

d The salt dissociates to acid in water; therefore, this endpoint does not apply.

2,4-D = 2,4-dichlorophenoxyacetic acid