# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR 2,4-D

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 2,4-D.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for 2,4-D. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of 2,4-D have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of 2,4-D are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for 2,4-D released for public comment in 2017; thus, the literature search was restricted to studies published between February 2014 and January 2018. The following main databases were searched in January 2018:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for 2,4-D. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to 2,4-D were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2018 | ((“2,4-Dichlorophenoxyacetic Acid”[mh] OR 94-75-7[rn] OR 14214-89-2[rn] OR 2307-553[rn] OR 2702-72-9[rn] OR 3766-27-6[rn]) AND (2014/02/01 : 3000[dp] OR 2015/02/01 : 3000[mhda])) OR (((“(2,4-Dichlorophenoxy)acetic acid”[tw] OR “(2,4-dichlorophenoxy)-Acetic acid “[tw] OR “(2,4-Dichlorophenyloxy)acetic acid”[tw] OR “2-(2,4-Dichlorophenoxy)acetic acid”[tw] OR “2-(2,4-dichlorophenoxy)-Acetic acid”[tw] OR “2,4-D”[tw] OR “2,4-Dichlorophenoxyacetic acid”[tw] OR “2,4-dichloro-Phenoxyacetic acid”[tw] OR “2,4-Dichlorophenoxyethanoic acid”[tw] OR “2,4-PA”[tw] OR “Acme LV 4”[tw] OR “Acme LV 6”[tw] OR “Agricorn D”[tw] OR “Agrion”[tw] OR “Agrotect”[tw] OR “Aminopielik 50SL”[tw] OR “Aminopielik 720”[tw] OR “Ammonium 2,4-dichlorophenoxyacetate”[tw] OR “Amoxone”[tw] OR “Basalcoat”[tw] OR “BH 2,4-D”[tw] OR “Brush-rhap”[tw] OR “B-Selektonon”[tw] OR “Butoxy-D 3: 1 Liquid emulsifiable Brushkiller LV96”[tw] OR “Chipco turf herbicide D”[tw] OR “Chloroxone”[tw] OR “Citrus fix”[tw] OR “Crop rider”[tw] OR “Croprider”[tw] OR “Debroussaillant 600”[tw] OR “Ded-Weed LV-69”[tw] OR “Deherban”[tw] OR “De-Pester Ded-Weed LV-2”[tw] OR “Desormone”[tw] OR “Dezormon”[tw] OR “Dichlordon sodium”[tw] OR “Dichlorophenoxyacetic acid”[tw] OR “Diclordon”[tw] OR “Diconirt”[tw] OR “Diconirt D”[tw] OR “Dicopur”[tw] OR “Dikonirt”[tw] OR “Dikonirt D”[tw] OR “Dormon”[tw] OR “Dormone”[tw] OR “Emulsamine”[tw] OR “ENT 8,538”[tw] OR “Envert DT”[tw] OR “Esteron 44 weed killer”[tw] OR “Esteron 76 BE”[tw] OR “Estone”[tw] OR “Fernesta”[tw] OR “Fernimine”[tw] OR “Fernoxene”[tw] OR “Fernoxone”[tw] OR “Ferxone”[tw] OR “Foredex 75”[tw] OR “Green Cross Weed-No-More 80”[tw] OR “Herbidal”[tw] OR “Hivol-44”[tw] OR “HM 2010”[tw] OR “Hormit”[tw] OR “Huragan”[tw] OR “Invesamina 480SL”[tw] OR “Ipaner”[tw] OR “Isadiamineyeom”[tw] OR “Kar D”[tw] OR “Lawn-keep”[tw] OR “Lithium 2,4-dichlorophenoxyacetate”[tw] OR “Macondray”[tw] OR “Macrondray”[tw] OR “Monosan”[tw] OR “Monosan herbi”[tw] OR “Mota Maskros”[tw] OR “Moxone”[tw] OR “Netagrone”[tw] OR “Netagrone 600”[tw] OR “NSC 2925”[tw] OR “Pennamine D”[tw] OR “Pielik”[tw] OR “Pielik E”[tw] OR “Planotox”[tw] OR “Plantgard”[tw] OR “Potassium (2,4-dichlorophenoxy)acetate”[tw] OR “Potassium 2,4-dichlorophenoxyacetate”[tw] OR “Profiamina”[tw] OR “Red Devil Dry Weed Killer”[tw] OR “R-H Weed Rhap 20”[tw] OR “Scott’s 4-XD Weed Control”[tw] OR “Silvaprop 1”[tw] OR “Sodium (2,4-dichlorophenoxy)acetate”[tw] OR “Sodium 2,4-dichlorophenoxyacetate”[tw] OR “Sodium diclordon”[tw] OR “Solushan”[tw] OR “Spray-hormite”[tw] OR “Spritz-hormit”[tw] OR “Superormone concentre”[tw] OR “Taficide”[tw] OR “Tiller S”[tw] OR “Tornado DF”[tw] OR “Tributon”[tw] OR “U 46D”[tw] OR “U 46DP”[tw] OR “U-46-D-Fluid”[tw] OR “U-5043”[tw] OR “Vergemaster”[tw] OR “Verton 2D”[tw] OR “Verton 38”[tw] OR “Vidon 638”[tw] OR “Visko-rhap low drift herbicides”[tw] OR “Visko-rhap low volatile 4l”[tw] OR “Weed TOX”[tw] OR “Weed-Ag-Bar”[tw] OR “Weedatul”[tw] OR “Weed-B-gon”[tw] OR “Weedez Wonder BAR”[tw] OR “Weedone”[tw] OR “Weed-rhap”[tw] OR “Weed-Rhap A-4”[tw] OR “Weed-Rhap B-266”[tw] OR “Weed-Rhap B-4”[tw] OR “Weed-Rhap I-3.34”[tw] OR “Weed-Rhap LV-4-0”[tw] OR “Weedtrol”[tw]) AND (2014/02/01 : 3000[dp] OR 2015/02/01 : 3000[crdat] OR 2015/02/01 : 3000[edat])) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “pharmacology”[sh:noexp] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR “Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic “[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh] OR cancer[sb] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR “toxicokinetics”[mh:noexp])) OR (((“(2,4-Dichlorophenoxy)acetic acid”[tw] OR “(2,4-dichlorophenoxy)-Acetic acid “[tw] OR “(2,4-Dichlorophenyloxy)acetic acid”[tw] OR “2-(2,4-Dichlorophenoxy)acetic acid”[tw] OR “2-(2,4-dichlorophenoxy)-Acetic acid”[tw] OR “2,4-D”[tw] OR “2,4-Dichlorophenoxyacetic acid”[tw] OR “2,4-dichloroPhenoxyacetic acid”[tw] OR “2,4-Dichlorophenoxyethanoic acid”[tw] OR “2,4-PA”[tw] OR “Acme LV 4”[tw] OR “Acme LV 6”[tw] OR “Agricorn D”[tw] OR “Agrion”[tw] OR “Agrotect”[tw] OR “Aminopielik 50SL”[tw] OR “Aminopielik 720”[tw] OR “Ammonium 2,4-dichlorophenoxyacetate”[tw] OR “Amoxone”[tw] OR “Basalcoat”[tw] OR “BH 2,4-D”[tw] OR “Brush-rhap”[tw] OR “B-Selektonon”[tw] OR “Butoxy-D 3: 1 Liquid emulsifiable Brushkiller LV96”[tw] OR “Chipco turf herbicide D”[tw] OR “Chloroxone”[tw] OR “Citrus fix”[tw] OR “Crop rider”[tw] OR “Croprider”[tw] OR “Debroussaillant 600”[tw] OR “Ded-Weed LV69”[tw] OR “Deherban”[tw] OR “De-Pester Ded-Weed LV-2”[tw] OR “Desormone”[tw] OR “Dezormon”[tw] OR “Dichlordon sodium”[tw] OR “Dichlorophenoxyacetic acid”[tw] OR “Diclordon”[tw] OR “Diconirt”[tw] OR “Diconirt D”[tw] OR “Dicopur”[tw] OR “Dikonirt”[tw] OR “Dikonirt D”[tw] OR “Dormon”[tw] OR “Dormone”[tw] OR “Emulsamine”[tw] OR “ENT 8,538”[tw] OR “Envert DT”[tw] OR “Esteron 44 weed killer”[tw] OR “Esteron 76 BE”[tw] OR “Estone”[tw] OR “Fernesta”[tw] OR “Fernimine”[tw] OR “Fernoxene”[tw] OR “Fernoxone”[tw] OR “Ferxone”[tw] OR “Foredex 75”[tw] OR “Green Cross Weed-No-More 80”[tw] OR “Herbidal”[tw] OR “Hivol-44”[tw] OR “HM 2010”[tw] OR “Hormit”[tw] OR “Huragan”[tw] OR “Invesamina 480SL”[tw] OR “Ipaner”[tw] OR “Isadiamineyeom”[tw] OR “Kar D”[tw] OR “Lawn-keep”[tw] OR “Lithium 2,4-dichlorophenoxyacetate”[tw] OR “Macondray”[tw] OR “Macrondray”[tw] OR “Monosan”[tw] OR “Monosan herbi”[tw] OR “Mota Maskros”[tw] OR “Moxone”[tw] OR “Netagrone”[tw] OR “Netagrone 600”[tw] OR “NSC 2925”[tw] OR “Pennamine D”[tw] OR “Pielik”[tw] OR “Pielik E”[tw] OR “Planotox”[tw] OR “Plantgard”[tw] OR “Potassium (2,4-dichlorophenoxy)acetate”[tw] OR “Potassium 2,4-dichlorophenoxyacetate”[tw] OR “Profiamina”[tw] OR “Red Devil Dry Weed Killer”[tw] OR “R-H Weed Rhap 20”[tw] OR “Scott’s 4-XD Weed Control”[tw] OR “Silvaprop 1”[tw] OR “Sodium (2,4-dichlorophenoxy)acetate”[tw] OR “Sodium 2,4-dichlorophenoxyacetate”[tw] OR “Sodium diclordon”[tw] OR “Solushan”[tw] OR “Spray-hormite”[tw] OR “Spritzhormit”[tw] OR “Superormone concentre”[tw] OR “Taficide”[tw] OR “Tiller S”[tw] OR “Tornado DF”[tw] OR “Tributon”[tw] OR “U 46D”[tw] OR “U 46DP”[tw] OR “U-46-DFluid”[tw] OR “U-5043”[tw] OR “Vergemaster”[tw] OR “Verton 2D”[tw] OR “Verton 38”[tw] OR “Vidon 638”[tw] OR “Visko-rhap low drift herbicides”[tw] OR “Visko-rhap low volatile 4l”[tw] OR “Weed TOX”[tw] OR “Weed-Ag-Bar”[tw] OR “Weedatul”[tw] OR “Weed-Bgon”[tw] OR “Weedez Wonder BAR”[tw] OR “Weedone”[tw] OR “Weed-rhap”[tw] OR “Weed-Rhap A-4”[tw] OR “Weed-Rhap B-266”[tw] OR “Weed-Rhap B-4”[tw] OR “Weed-Rhap I-3.34”[tw] OR “Weed-Rhap LV-4-0”[tw] OR “Weedtrol”[tw]) AND (2014/02/01 : 3000[dp] OR 2015/02/01 : 3000[crdat] OR 2015/02/01 : 3000[edat])) NOT medline[sb]); “2,4-Dichlorophenoxyacetic Acid”[mh] AND “Adverse Outcome Pathways”[mh]; (“5742-19-8”[rn] OR “2008-39-1”[rn] OR “5742-17-6”[rn] OR “18584-79-7”[rn] OR “1929-73-3”[rn] OR “1928-43-4”[rn] OR “94-11-1”[rn] OR “2,4-D amine”[nm] OR “butoxyethanol ester of 2,4-dichlorophenoxyacetic acid”[nm] OR “2-ethylhexyl 2,4-dichlorophenoxyacetate”[nm]) OR “2,4-D Bis(2-hydroxyethyl)ammonium”[tw] OR “2,4-D Diethanolamine”[tw] OR “2,4-D Diethanolamine salt”[tw] OR “2,4-D-Bis(2hydroxyethyl)ammonium”[tw] OR “2,4-D-diolamine”[tw] OR “2,4-Dichlorophenoxyacetic acid diethanolamine salt”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2,2’-iminobis(ethanol) (1:1)”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, diethanolamine salt”[tw] OR “Bis(2-hydroxyethyl)ammonium 2,4-dichlorophenoxyacetate”[tw] OR “Diethanolamine 2,4-dichlorophenoxyacetate”[tw] OR “Diethanolamine salt of 2,4-dichlorophenoxyacetic acid solution”[tw] OR “(2,4-Dichlorophenoxy)acetic acid compd. with isopropylamine”[tw] OR “(2,4-Dichlorophenoxy)acetic acid isopropylamine salt”[tw] OR “2,4-D isopropylamine”[tw] OR “2,4-D isopropylamine salt”[tw] OR “2,4-Disopropylammonium”[tw] OR “2-Propanamine, (2,4-dichlorophenoxy)acetate”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2-propanamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with isopropylamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropylamine salt”[tw] OR “Isopropylamine 2,4-dichlorophenoxyacetate”[tw] OR “Isopropylamine, compd. with (2,4-dichlorophenoxy)acetic acid”[tw] OR “(2,4-Dichlorophenoxy)acetic acid compd. with 1,1’,1-nitrilotris[2-propanol]”[tw] OR “2,4-D Triisopropanolamine”[tw] OR “2,4-D triisopropanolamine salt”[tw] OR “2,4-D triisopropanolamine sodium salt”[tw] OR “2,4-D triisopropanolammonium salt”[tw] OR “2,4-D, triisopropanolamine salt”[tw] OR “2,4-D-tris(2-hydroxypropyl)ammonium”[tw] OR “2,4-D-Trisopropyl salt”[tw] OR “2,4-Dichlorophenoxyacetic acid triisopropanolamine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid, triisopropanolamine salt solution”[tw] OR “2-Propanol, 1,1’,1”-nitrilotri-, (2,4-dichlorophenoxy)acetate (salt)”[tw] OR “2-Propanol, 1,1’,1”-nitrilotris-, (2,4-dichlorophenoxy)acetate (salt)”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotri-2-propanol”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotris(2-propanol)”[tw] OR “Triisopropanolamine 2,4-dichlorophenoxyacetate”[tw] OR “(2,4-Dichlorophenoxy)acetic acid, 1-methylethyl ester”[tw] OR “2,4-D ester”[tw] OR “2,4-D esters”[tw] OR “2,4-D Isopropyl ester”[tw] OR “2,4-D, isopropyl ester”[tw] OR “2,4-D-ester”[tw] OR “2,4-D-Isopropyl”[tw] OR “2,4-Dichlorophenoxyacetic acid ester”[tw] OR “2,4-Dichlorophenoxyacetic acid, 1-methylethyl ester”[tw] OR “2,4-Dichlorophenoxyacetic acid, isopropyl ester”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, 1-methylethyl ester”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropyl ester”[tw] OR “Amchem Weed Killer 650”[tw] OR “Barber’s Weed Killer (Ester Formulation)”[tw] OR “Bridgeport Spot Weed Killer”[tw] OR “Chemical Insecticide’s Isopropyl Ester of 2,4-D Liquid Concentrate”[tw] OR “Crop Rider 3-34D-2”[tw] OR “Crop Rider 3.34D”[tw] OR “Esteron 44”[tw] OR “Isopropyl (2,4-dichlorophenoxy)acetate”[tw] OR “Isopropyl 2,4-D ester”[tw] OR “Isopropyl 2,4-dichlorophenoxyacetate”[tw] OR “Isopropylester kyseliny 2,4-dichlorfenoxyoctove”[tw] OR “Isopropylester kyseliny 2,4-dichlorfenoxyoctove [Czech]”[tw] OR “Monsanto 2,4-D Isopropyl Ester”[tw] OR “Niagara Estasol”[tw] OR “Parsons 2,4-D Weed Killer Isopropyl Ester”[tw] OR “Swift’s Gold Bear 44 Ester”[tw] OR “Weedone 128”[tw]; (“(2,4-Dichlorophenoxy)acetic acid dimethylamine”[tw] OR “(2,4-Dichlorophenoxy)acetic acid dimethylamine salt”[tw] OR “2,4-D amine”[tw] OR “2,4-D amine salt”[tw] OR “2,4-D dimethylamine”[tw] OR “2,4-D dimethylamine salt”[tw] OR “2,4-D DMA”[tw] OR “2,4-D N,N-dimethylamine”[tw] OR “2,4-D, alkanolamine salt”[tw] OR “2,4-D-dimethylammonium”[tw] OR “2,4-Diamin SL”[tw] OR “2,4-Dichlorophenoxy)acetic acid compd. with Nmethylmethanamine”[tw] OR “2,4-Dichlorophenoxy)acetic acid dimethylamine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid dimethylamine”[tw] OR “2,4-Dichlorophenoxyacetic acid dimethylamine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid, dimethyl amine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid, dimethylamine salt solution”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with dimethylamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with N-methylmethanamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with dimethylamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with N-methylmethanamine”[tw] OR “Dimethylamine 2,4-dichlorophenoxyacetate”[tw] OR “Dimethylamine salt of 2,4-dichlorophenoxyacetic acid solution”[tw] OR “Dimethylamine, (2,4-dichlorophenoxy)acetate”[tw] OR “Dimethylammonium 2,4-dichlorophenoxyacetate”[tw] OR “Methanamine, N-methyl-, (2,4-dichlorophenoxy)acetate”[tw] OR “N-Methylmethanamine (2,4-dichlorophenoxy)acetate”[tw] OR “N-Methylmethanamine 2,4-dichlorophenoxyacetate”[tw] OR “Alkano amine salt of 2,4-D”[tw] OR “Amicide”[tw] OR “Amine-2,4-D”[tw] OR “Aminol”[tw] OR “Aminopielek 720”[tw] OR “Aminopielik 600SL”[tw] OR “Aminoprelik 39”[tw] OR “Amisol”[tw] OR “Banvel 3 Liquid Herbicide”[tw] OR “Banvel-720”[tw] OR “Barber’s Weed Killer”[tw] OR “Best 4 Servis Brand Lawn Weed Killer”[tw] OR “Bladex G”[tw] OR “Blitz 64”[tw] OR “Brabant 2,4-D amine”[tw] OR “Chipman 2,4-D Amine No. 4”[tw] OR “Chipman Lawn Weedkiller”[tw] OR “Chipman’s 2,4-D amine No. 4”[tw] OR “Clean Crop 2,4-D Amine 500”[tw] OR “Co-op Premium Lawn Weed Killer”[tw] OR “D 50 (pesticide)”[tw] OR “Ded-Weed Sulv”[tw] OR “Desormone”[tw] OR “Diamond Shamrock Amine 6D”[tw] OR “Dikamin D”[tw] OR “DMA 4”[tw] OR “DMA 6”[tw] OR “DMA-2,4-D”[tw] OR “Dma-4”[tw] OR “Dow DMA-4”[tw] OR “Dow Formula 40”[tw] OR “Du Pont Lawn Weed Killer”[tw] OR “Du Pont Turf Food With Weed Killer”[tw] OR “Du Pont Weed Killer No. 2”[tw] OR “Farmco D 50”[tw] OR “Farmco D-50”[tw] OR “Floro Tox 2,4-D Amine Weed Killer”[tw] OR “Formula 40”[tw] OR “FS Amine 400 Weed Killer”[tw] OR “Green Cross Killex Spot Weeder Pressurized Spray”[tw] OR “Green Cross Poison Ivy Killer”[tw] OR “Herbitex”[tw] OR “Hormin”[tw] OR “Liquid Clearit Vegetation Killer”[tw] OR “Liquid Wonder Weeder”[tw] OR “Manco Kill-Weed”[tw] OR “Marquette Herbitex Plus”[tw] OR “Mecoturf Plus 2,4-D Liquid Weedkiller”[tw] OR “Monosan”[tw] OR “Monsanto 2,4-D Amine”[tw] OR “Morselect”[tw] OR “Norkem 40t”[tw] OR “Ortho Super Weed-B-Gon Spray”[tw] OR “Pacific Cooperatives P 2,4-D Amine Weed Killer”[tw] OR “Parsons 2,4-D Weed Killer”[tw] OR “Parsons 2,4-D Weed Killer No. 40”[tw] OR “Phordene”[tw] OR “Reed amine 400”[tw] OR “Shirweed 500”[tw] OR “Spraygraze”[tw] OR “Spritz-Hormin”[tw] OR “Sure Death 2,4-D Amine Weedkiller”[tw] OR “Techne 2,4-D Amine Weed Killer”[tw] OR “U 46D Fluid”[tw] OR “U-46 D-Fluid”[tw] OR “Vigoro Dandelions Killer”[tw] OR “Weed-Rhap A-4D”[tw] OR “Weedar 64”[tw] OR “Weedar 96”[tw] OR “Weedkiller D”[tw] OR “Wilbur-Ellis 2,4-D Amine 500”[tw] OR “Wilson’s Multi-Weeder”[tw] OR “Zehrung 2,4-D Selective Amine Weed Killer”[tw] OR “(2,4-Dichlorophenoxy)acetic acid butoxyethyl ester”[tw] OR “(2,4-Dichlorophenoxy)acetic acid, 2-butoxyethyl ester”[tw] OR “2,4-D (BEE)”[tw] OR “2,4-D (BOEE)”[tw] OR “2,4-D 2-butoxyethyl ester”[tw] OR “2,4-D butoxyethanol”[tw] OR “2,4-D butoxyethanol ester”[tw] OR “2,4-D butoxyethyl ester”[tw] OR “2,4-D esters”[tw] OR “2,4-D isobutoxyethanol”[tw] OR “2,4-D, BEE”[tw] OR “2,4-D, butoxyethanol ester”[tw] OR “2,4-D, butoxyethyl ester”[tw] OR “2,4-D-(2-Butoxyethyl)”[tw] OR “2,4-D-BEE”[tw] OR “2,4-Dbutotyl”[tw] OR “2,4-DBE”[tw] OR “2,4-DBEE”[tw] OR “2,4-Dichlorophenoxyacetic acid 2-Butoxyethyl ester”[tw] OR “2,4-Dichlorophenoxyacetic acid butoxyethanol ester”[tw] OR “2,4-Dichlorophenoxyacetic acid ethylene glycol butyl ether ester”[tw] OR “2,4-Dichlorophenoxyacetic acid, butoxyethyl ester”[tw] OR “2,4-Dichlorophenoxyacetic acids”[tw] OR “2-Butoxyethyl 2,4-dichlorophenoxyacetate”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, butoxyethyl ester”[tw] OR “Aqua-Kleen”[tw] OR “BEE 2,4-D”[tw] OR “Bladex-B”[tw] OR “Brush killer 64”[tw] OR “Butoxy-D 3”[tw] OR “Butoxyethanol ester of (2,4-dichlorophenoxy)acetic acid”[tw] OR “Butoxyethanol ester of 2,4-dichlorophenoxyacetic acid”[tw] OR “Butoxyethyl 2,4-dichlorophenoxyacetate”[tw] OR “Butoxyethyl ester of 2,4-dichlorophenoxy acetic acid”[tw] OR “Esteron 99 Concentrate”[tw] OR “Lo-Estasol”[tw] OR “Planotox”[tw] OR “Silvaprop 1”[tw] OR “Weed-Rhap LV-4D”[tw] OR “Weedone 100 Emulsifiable”[tw] OR “Weedone 638”[tw] OR “Weedone LV 4”[tw] OR “Weedone LV-6”[tw] OR “Weedone LV4”[tw] OR “(2,4-Dichlorophenoxy)acetic acid 2-ethylhexyl ester”[tw] OR “2,4-D 2-Ethylhexyl ester”[tw] OR “2,4-D Ethylhexyl ester”[tw] OR “2,4-D-2-ethylhexyl”[tw] OR “2-Ethylhexyl (2,4-dichlorophenoxy)acetate”[tw] OR “2-Ethylhexyl 2,4-dichlorophenoxyacetate”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “pharmacology”[sh:noexp] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR “Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic “[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh] OR cancer[sb] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR “toxicokinetics”[mh:noexp]); (“(2,4-Dichlorophenoxy)acetic acid dimethylamine”[tw] OR “(2,4-Dichlorophenoxy)acetic acid dimethylamine salt”[tw] OR “2,4-D amine”[tw] OR “2,4-D amine salt”[tw] OR “2,4-D dimethylamine”[tw] OR “2,4-D dimethylamine salt”[tw] OR “2,4-D DMA”[tw] OR “2,4-D N,N-dimethylamine”[tw] OR “2,4-D, alkanolamine salt”[tw] OR “2,4-D-dimethylammonium”[tw] OR “2,4-Diamin SL”[tw] OR “2,4-Dichlorophenoxy)acetic acid compd. with N-methylmethanamine”[tw] OR “2,4-Dichlorophenoxy)acetic acid dimethylamine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid dimethylamine”[tw] OR “2,4-Dichlorophenoxyacetic acid dimethylamine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid, dimethyl amine salt”[tw] OR “2,4-Dichlorophenoxyacetic acid, dimethylamine salt solution”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with dimethylamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with N-methylmethanamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with dimethylamine”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with N-methylmethanamine”[tw] OR “Dimethylamine 2,4-dichlorophenoxyacetate”[tw] OR “Dimethylamine salt of 2,4-dichlorophenoxyacetic acid solution”[tw] OR “Dimethylamine, (2,4-dichlorophenoxy)acetate”[tw] OR “Dimethylammonium 2,4-dichlorophenoxyacetate”[tw] OR “Methanamine, N-methyl-, (2,4-dichlorophenoxy)acetate”[tw] OR “N-Methylmethanamine (2,4-dichlorophenoxy)acetate”[tw] OR “N-Methylmethanamine 2,4-dichlorophenoxyacetate”[tw] OR “Alkano amine salt of 2,4-D”[tw] OR “Amicide”[tw] OR “Amine-2,4-D”[tw] OR “Aminol”[tw] OR “Aminopielek 720”[tw] OR “Aminopielik 600SL”[tw] OR “Aminoprelik 39”[tw] OR “Amisol”[tw] OR “Banvel 3 Liquid Herbicide”[tw] OR “Banvel-720”[tw] OR “Barber’s Weed Killer”[tw] OR “Best 4 Servis Brand Lawn Weed Killer”[tw] OR “Bladex G”[tw] OR “Blitz 64”[tw] OR “Brabant 2,4-D amine”[tw] OR “Chipman 2,4-D Amine No. 4”[tw] OR “Chipman Lawn Weedkiller”[tw] OR “Chipman’s 2,4-D amine No. 4”[tw] OR “Clean Crop 2,4-D Amine 500”[tw] OR “Co-op Premium Lawn Weed Killer”[tw] OR “D 50 (pesticide)”[tw] OR “Ded-Weed Sulv”[tw] OR “Desormone”[tw] OR “Diamond Shamrock Amine 6D”[tw] OR “Dikamin D”[tw] OR “DMA 4”[tw] OR “DMA 6”[tw] OR “DMA-2,4-D”[tw] OR “Dma-4”[tw] OR “Dow DMA-4”[tw] OR “Dow Formula 40”[tw] OR “Du Pont Lawn Weed Killer”[tw] OR “Du Pont Turf Food With Weed Killer”[tw] OR “Du Pont Weed Killer No. 2”[tw] OR “Farmco D 50”[tw] OR “Farmco D-50”[tw] OR “Floro Tox 2,4-D Amine Weed Killer”[tw] OR “Formula 40”[tw] OR “FS Amine 400 Weed Killer”[tw] OR “Green Cross Killex Spot Weeder Pressurized Spray”[tw] OR “Green Cross Poison Ivy Killer”[tw] OR “Herbitex”[tw] OR “Hormin”[tw] OR “Liquid Clearit Vegetation Killer”[tw] OR “Liquid Wonder Weeder”[tw] OR “Manco Kill-Weed”[tw] OR “Marquette Herbitex Plus”[tw] OR “Mecoturf Plus 2,4-D Liquid Weedkiller”[tw] OR “Monosan”[tw] OR “Monsanto 2,4-D Amine”[tw] OR “Morselect”[tw] OR “Norkem 40t”[tw] OR “Ortho Super Weed-B-Gon Spray”[tw] OR “Pacific Cooperatives P 2,4-D Amine Weed Killer”[tw] OR “Parsons 2,4-D Weed Killer”[tw] OR “Parsons 2,4-D Weed Killer No. 40”[tw] OR “Phordene”[tw] OR “Reed amine 400”[tw] OR “Shirweed 500”[tw] OR “Spraygraze”[tw] OR “Spritz-Hormin”[tw] OR “Sure Death 2,4-D Amine Weedkiller”[tw] OR “Techne 2,4-D Amine Weed Killer”[tw] OR “U 46D Fluid”[tw] OR “U-46 D-Fluid”[tw] OR “Vigoro Dandelions Killer”[tw] OR “Weed-Rhap A-4D”[tw] OR “Weedar 64”[tw] OR “Weedar 96”[tw] OR “Weedkiller D”[tw] OR “Wilbur-Ellis 2,4-D Amine 500”[tw] OR “Wilson’s Multi-Weeder”[tw] OR “Zehrung 2,4-D Selective Amine Weed Killer”[tw] OR “(2,4-Dichlorophenoxy)acetic acid butoxyethyl ester”[tw] OR “(2,4-Dichlorophenoxy)acetic acid, 2-butoxyethyl ester”[tw] OR “2,4-D (BEE)”[tw] OR “2,4-D (BOEE)”[tw] OR “2,4-D 2-butoxyethyl ester”[tw] OR “2,4-D butoxyethanol”[tw] OR “2,4-D butoxyethanol ester”[tw] OR “2,4-D butoxyethyl ester”[tw] OR “2,4-D esters”[tw] OR “2,4-D isobutoxyethanol”[tw] OR “2,4-D, BEE”[tw] OR “2,4-D, butoxyethanol ester”[tw] OR “2,4-D, butoxyethyl ester”[tw] OR “2,4-D-(2-Butoxyethyl)”[tw] OR “2,4-D-BEE”[tw] OR “2,4-D-butotyl”[tw] OR “2,4-DBE”[tw] OR “2,4-DBEE”[tw] OR “2,4-Dichlorophenoxyacetic acid 2-Butoxyethyl ester”[tw] OR “2,4-Dichlorophenoxyacetic acid butoxyethanol ester”[tw] OR “2,4-Dichlorophenoxyacetic acid ethylene glycol butyl ether ester”[tw] OR “2,4-Dichlorophenoxyacetic acid, butoxyethyl ester”[tw] OR “2,4-Dichlorophenoxyacetic acids”[tw] OR “2-Butoxyethyl 2,4-dichlorophenoxyacetate”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, butoxyethyl ester”[tw] OR “Aqua-Kleen”[tw] OR “BEE 2,4-D”[tw] OR “Bladex-B”[tw] OR “Brush killer 64”[tw] OR “Butoxy-D 3”[tw] OR “Butoxyethanol ester of (2,4-dichlorophenoxy)acetic acid”[tw] OR “Butoxyethanol ester of 2,4-dichlorophenoxyacetic acid”[tw] OR “Butoxyethyl 2,4-dichlorophenoxyacetate”[tw] OR “Butoxyethyl ester of 2,4-dichlorophenoxy acetic acid”[tw] OR “Esteron 99 Concentrate”[tw] OR “Lo-Estasol”[tw] OR “Planotox”[tw] OR “Silvaprop 1”[tw] OR “Weed-Rhap LV-4D”[tw] OR “Weedone 100 Emulsifiable”[tw] OR “Weedone 638”[tw] OR “Weedone LV 4”[tw] OR “Weedone LV-6”[tw] OR “Weedone LV4”[tw] OR “(2,4-Dichlorophenoxy)acetic acid 2-ethylhexyl ester”[tw] OR “2,4-D 2-Ethylhexyl ester”[tw] OR “2,4-D Ethylhexyl ester”[tw] OR “2,4-D-2-ethylhexyl”[tw] OR “2-Ethylhexyl (2,4-dichlorophenoxy)acetate”[tw] OR “2-Ethylhexyl 2,4-dichlorophenoxyacetate”[tw] OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester”[tw]) NOT medline[sb]
Toxline
01/2018 | Limited 2014-present:; “(2,4-Dichlorophenoxy)acetic acid” OR “(2,4-dichlorophenoxy)-Acetic acid” OR “(2,4-Dichlorophenyloxy)acetic acid” OR “2-(2,4-Dichlorophenoxy)acetic acid” OR “2-(2,4-dichlorophenoxy)-Acetic acid” OR “2,4-D” OR “2,4-Dichlorophenoxyacetic acid” OR “2,4-dichloro-Phenoxyacetic acid” OR “2,4-Dichlorophenoxyethanoic acid” OR “2,4-PA” OR “Acme LV 4” OR “Acme LV 6” OR “Agricorn D”; Limited 2014-present:; “Agrion” OR “Agrotect” OR “Aminopielik 50SL” OR “Aminopielik 720” OR “Ammonium 2,4-dichlorophenoxyacetate” OR “Amoxone” OR “Basalcoat” OR “BH 2,4-D” OR “Brush-rhap” OR “B-Selektonon” OR “Butoxy-D 3: 1 Liquid emulsifiable Brushkiller LV96” OR “Chipco turf herbicide D” OR “Chloroxone” OR “Citrus fix” OR “Crop rider” OR “Croprider” OR “Debroussaillant 600”; Limited 2014-present:; “Ded-Weed LV-69” OR “Deherban” OR “De-Pester Ded-Weed LV-2” OR “Desormone” OR “Dezormon” OR “Dichlordon sodium” OR “Dichlorophenoxyacetic acid” OR “Diclordon” OR “Diconirt” OR “Diconirt D” OR “Dicopur” OR “Dikonirt” OR “Dikonirt D” OR “Dormon” OR “Dormone” OR “Emulsamine” OR “ENT 8,538” OR “Envert DT” OR “Esteron 44 weed killer” OR “Esteron 76 BE” OR “Estone” OR “Fernesta”; Limited 2014-present:; “Fernimine” OR “Fernoxene” OR “Fernoxone” OR “Ferxone” OR “Foredex 75” OR “Green Cross Weed-No-More 80” OR “Herbidal” OR “Hivol-44” OR “HM 2010” OR “Hormit” OR “Huragan” OR “Invesamina 480SL” OR “Ipaner” OR “Isadiamineyeom” OR “Kar D” OR “Lawn-keep” OR “Lithium 2,4-dichlorophenoxyacetate” OR “Macondray” OR “Macrondray” OR “Monosan” OR “Monosan herbi”; Limited 2014-present:; “Mota Maskros” OR “Moxone” OR “Netagrone” OR “Netagrone 600” OR “NSC 2925” OR “Pennamine D” OR “Pielik” OR “Pielik E” OR “Planotox” OR “Plantgard” OR “Potassium (2,4-dichlorophenoxy)acetate” OR “Potassium 2,4-dichlorophenoxyacetate” OR “Profiamina” OR “Red Devil Dry Weed Killer” OR “R-H Weed Rhap 20” OR “Scott’s 4-XD Weed Control” OR “Silvaprop 1”; Limited 2014-present:; “Sodium (2,4-dichlorophenoxy)acetate” OR “Sodium 2,4-dichlorophenoxyacetate” OR “Sodium diclordon” OR “Solushan” OR “Spray-hormite” OR “Spritz-hormit” OR “Superormone concentre” OR “Taficide” OR “Tiller S” OR “Tornado DF” OR “Tributon” OR “U 46D” OR “U 46DP” OR “U-46-D-Fluid” OR “U-5043” OR “Vergemaster” OR “Verton 2D” OR “Verton 38” OR “Vidon 638”; Limited 2014-present:; “Visko-rhap low drift herbicides” OR “Visko-rhap low volatile 4l” OR “Weed TOX” OR “Weed-Ag-Bar” OR “Weedatul” OR “Weed-B-gon” OR “Weedez Wonder BAR” OR “Weedone” OR “Weed-rhap” OR “Weed-Rhap A-4” OR “Weed-Rhap B-266” OR “Weed-Rhap B-4” OR “Weed-Rhap I-3.34” OR “Weed-Rhap LV-4-0” OR “Weedtrol” OR 94-75-7[rn] OR 14214-89-2[rn] OR 2307-55-3[rn] OR 2702-72-9[rn] OR 3766-27-6[rn]; “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2,2’-iminobis(ethanol) (1:1)” OR “Acetic acid, (2,4-dichlorophenoxy)-, diethanolamine salt” OR “Bis(2-hydroxyethyl)ammonium 2,4-dichlorophenoxyacetate” OR “Diethanolamine 2,4-dichlorophenoxyacetate” OR “2,4-Diamin SL” OR “2,4-Dichlorophenoxy)acetic acid compd. with N-methylmethanamine” OR “2,4-Dichlorophenoxy)acetic acid dimethylamine salt”; “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with N-methylmethanamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with N-methylmethanamine” OR “Dimethylamine 2,4-dichlorophenoxyacetate” OR “Dimethylamine, (2,4-dichlorophenoxy)acetate”; “Dimethylammonium 2,4-dichlorophenoxyacetate” OR “Methanamine, N-methyl-, (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine 2,4-dichlorophenoxyacetate” OR “Alkano amine salt of 2,4-D” OR “Amicide” OR “Amine-2,4-D” OR “Aminol” OR “Aminopielek 720” OR “Aminopielik 600SL” OR “Aminoprelik 39”; “Amisol” OR “Banvel 3 Liquid Herbicide” OR “Banvel-720” OR “Barber’s Weed Killer” OR “Best 4 Servis Brand Lawn Weed Killer” OR “Bladex G” OR “Blitz 64” OR “Chipman Lawn Weedkiller” OR “Co-op Premium Lawn Weed Killer” OR “D 50 pesticide” OR “Ded-Weed Sulv” OR “Desormone” OR “Diamond Shamrock Amine 6D” OR “Dikamin D” OR “DMA 4” OR “DMA 6” OR “DMA-2,4-D” OR “Dma-4” OR “Dow DMA-4”; “Dow Formula 40” OR “Du Pont Lawn Weed Killer” OR “Du Pont Turf Food With Weed Killer” OR “Du Pont Weed Killer No. 2” OR “Farmco D 50” OR “Farmco D-50” OR “Formula 40” OR “FS Amine 400 Weed Killer” OR “Green Cross Killex Spot Weeder Pressurized Spray” OR “Green Cross Poison Ivy Killer” OR “Herbitex” OR “Hormin” OR “Liquid Clearit Vegetation Killer” OR “Liquid Wonder Weeder” OR “Manco Kill-Weed”; “Marquette Herbitex Plus” OR “Monosan” OR “Morselect” OR “Norkem 40t” OR “Ortho Super Weed-B-Gon Spray” OR “Phordene” OR “Reed amine 400” OR “Shirweed 500” OR “Spraygraze” OR “Spritz-Hormin” OR “Vigoro Dandelions Killer” OR “Weed-Rhap A-4D” OR “Weedar 64” OR “Weedar 96” OR “Weedkiller D” OR “Wilson’s Multi-Weeder” OR “2-Propanamine, (2,4-dichlorophenoxy)acetate”; “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2-propanamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with isopropylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropylamine salt” OR “Isopropylamine 2,4-dichlorophenoxyacetate” OR “2-Propanol, 1,1’,1”-nitrilotri-, (2,4-dichlorophenoxy)acetate (salt)” OR “2-Propanol, 1,1’,1”-nitrilotris-, (2,4-dichlorophenoxy)acetate (salt)”; “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotri-2-propanol” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotris(2-propanol)” OR “Triisopropanolamine 2,4-dichlorophenoxyacetate” OR “2,4-DBE” OR “2,4-DBEE” OR “2,4-Dichlorophenoxyacetic acids” OR “2-Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester”; “Acetic acid, (2,4-dichlorophenoxy)-, butoxyethyl ester” OR “Aqua-Kleen” OR “BEE 2,4-D” OR “Bladex-B” OR “Brush killer 64” OR “Butoxy-D 3” OR “Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Butoxyethyl ester of 2,4-dichlorophenoxy acetic acid” OR “Esteron 99 Concentrate” OR “Lo-Estasol” OR “Planotox” OR “Silvaprop 1” OR “Weed-Rhap LV-4D” OR “Weedone 100 Emulsifiable” OR “Weedone 638”; “Weedone LV 4” OR “Weedone LV-6” OR “Weedone LV4” OR “2-Ethylhexyl (2,4-dichlorophenoxy)acetate” OR “2-Ethylhexyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, 1-methylethyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropyl ester” OR “Amchem Weed Killer 650”; “Barber’s Weed Killer (Ester Formulation)” OR “Bridgeport Spot Weed Killer” OR “Crop Rider 3-34D-2” OR “Crop Rider 3.34D” OR “Esteron 44” OR “Isopropyl (2,4-dichlorophenoxy)acetate” OR “Isopropyl 2,4-dichlorophenoxyacetate” OR “Niagara Estasol” OR “Swift’s Gold Bear 44 Ester” OR “Weedone 128” OR 5742-19-8[rn] OR 2008-39-1[rn] OR 5742-17-6[rn] OR 18584-79-7[rn] OR 1929-73-3[rn] OR 1928-43-4[rn] OR 94-11-1[rn]
Toxcenter
01/2018 | FILE ‘TOXCENTER’ ENTERED AT 10:27:31 ON 29 JAN 2018; CHARGED TO COST=EH011.05.LB.02.05; L1 14208 SEA FILE=TOXCENTER 94-75-7 OR 14214-89-2 OR 2307-55-3 OR 2702-72-9 OR 3766-27-6; L2 12917 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 12905 SEA FILE=TOXCENTER L2 NOT TSCATS/FS; L4 630 SEA FILE=TOXCENTER L3 AND ED>=20150201; L5 759 SEA FILE=TOXCENTER 5742-19-8 OR 2008-39-1 OR 5742-17-6 OR 18584-79-7 OR 1929-73-3 OR 1928-43-4 OR 94-11-1; L6 674 SEA FILE=TOXCENTER L5 NOT PATENT/DT; L7 674 SEA FILE=TOXCENTER L6 NOT TSCATS/FS; L8 431 SEA FILE=TOXCENTER L7 NOT L1; ACT TOXQUERY/Q; ---------; L9 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L10 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L11 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L12 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L13 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L14 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L15 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L16 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L17 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L18 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L19 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L20 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L21 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L22 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L23 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L24 QUE (ENDOCRIN? AND DISRUPT?); L25 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L26 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L27 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L28 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L29 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L30 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L31 QUE (NEPHROTOX? OR HEPATOTOX?); L32 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L33 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L34 QUE L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33; L35 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L36 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L37 QUE L34 OR L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; ---------; L40 355 SEA FILE=TOXCENTER L4 AND L39; L41 324 SEA FILE=TOXCENTER L7 AND L39; L42 186 SEA FILE=TOXCENTER L41 NOT L1; L43 321 SEA FILE=TOXCENTER L41 NOT L40; D SCAN L40; D SCAN L43

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
01/2018 | Compounds searched: 94-75-7; 14214-89-2; 2307-55-3; 2702-72-9; 3766-27-6; 5742-19-8; 2008-39-1; 5742-17-6; 18584-79-7; 1929-73-3; 1928-43-4; 94-11-1
NTP
01/2018 | Limited to dates 2014-1/2018 or not dated and Reports & Publications only. Terms searched:; “94-75-7” OR “14214-89-2” OR “2307-55-3” OR “2702-72-9” OR “3766-27-6”; “5742-19-8” OR “2008-39-1” OR “5742-17-6” OR “18584-79-7” OR “1929-73-3” OR “1928-43-4” OR “94-11-1”; “(2,4-Dichlorophenoxy)acetic acid” OR “(2,4-dichlorophenoxy)-Acetic acid” OR “(2,4-Dichlorophenyloxy)acetic acid” OR “2-(2,4-Dichlorophenoxy)acetic acid” OR “2-(2,4-dichlorophenoxy)-Acetic acid” OR “2,4-D” OR “2,4-Dichlorophenoxyacetic acid” OR “2,4-dichloro-Phenoxyacetic acid” OR “2,4-Dichlorophenoxyethanoic acid” OR “2,4-PA” OR “Acme LV 4” OR “Acme LV 6” OR “Agricorn D” OR “Agrion” OR “Agrotect” OR “Aminopielik 50SL” OR “Aminopielik 720” OR “Ammonium 2,4-dichlorophenoxyacetate” OR “Amoxone” OR “Basalcoat” OR “BH 2,4-D” OR “Brushrhap” OR “B-Selektonon” OR “Butoxy-D 3: 1 Liquid emulsifiable Brushkiller LV96” OR “Chipco turf herbicide D” OR “Chloroxone” OR “Citrus fix” OR “Crop rider” OR “Croprider” OR “Debroussaillant 600” OR “Ded-Weed LV-69” OR “Deherban” OR “De-Pester Ded-Weed LV-2” OR “Desormone” OR “Dezormon” OR “Dichlordon sodium” OR “Dichlorophenoxyacetic acid” OR “Diclordon” OR “Diconirt” OR “Diconirt D” OR “Dicopur” OR “Dikonirt” OR “Dikonirt D” OR “Dormon” OR “Dormone” OR “Emulsamine” OR “ENT 8,538” OR “Envert DT” OR “Esteron 44 weed killer” OR “Esteron 76 BE” OR “Estone” OR “Fernesta” OR “Fernimine” OR “Fernoxene” OR “Fernoxone” OR “Ferxone” OR “Foredex 75” OR “Green Cross Weed-No-More 80” OR “Herbidal” OR “Hivol-44” OR “HM 2010”; “Hormit” OR “Huragan” OR “Invesamina 480SL” OR “Ipaner” OR “Isadiamineyeom” OR “Kar D” OR “Lawn-keep” OR “Lithium 2,4-dichlorophenoxyacetate” OR “Macondray” OR “Macrondray” OR “Monosan” OR “Monosan herbi” OR “Mota Maskros” OR “Moxone” OR “Netagrone” OR “Netagrone 600” OR “NSC 2925” OR “Pennamine D” OR “Pielik” OR “Pielik E” OR “Planotox” OR “Plantgard” OR “Potassium (2,4-dichlorophenoxy)acetate” OR “Potassium 2,4-dichlorophenoxyacetate” OR “Profiamina” OR “Red Devil Dry Weed Killer” OR “R-H Weed Rhap 20” OR “Scott’s 4-XD Weed Control” OR “Silvaprop 1” OR “Sodium (2,4-dichlorophenoxy)acetate” OR “Sodium 2,4-dichlorophenoxyacetate” OR “Sodium diclordon” OR “Solushan” OR “Spray-hormite” OR “Spritz-hormit” OR “Superormone concentre” OR “Taficide” OR “Tiller S” OR “Tornado DF” OR “Tributon” OR “U 46D” OR “U 46DP” OR “U-46-D-Fluid” OR “U-5043” OR “Vergemaster” OR “Verton 2D” OR “Verton 38” OR “Vidon 638” OR “Visko-rhap low drift herbicides” OR “Visko-rhap low volatile 4l” OR “Weed TOX” OR “Weed-Ag-Bar” OR “Weedatul” OR “Weed-B-gon” OR “Weedez Wonder BAR” OR “Weedone” OR “Weed-rhap” OR “Weed-Rhap A-4” OR “Weed-Rhap B-266” OR “Weed-Rhap B-4” OR “Weed-Rhap I-3.34” OR “Weed-Rhap LV-4-0” OR “Weedtrol”; “Bis(2-hydroxyethyl)ammonium 2,4-dichlorophenoxyacetate” OR “Diethanolamine 2,4-dichlorophenoxyacetate” OR “2,4-Diamin SL” OR “2,4-Dichlorophenoxy)acetic acid compd. with N-methylmethanamine” OR “2,4-Dichlorophenoxy)acetic acid dimethylamine salt” OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with N-methylmethanamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with N-methylmethanamine” OR “Dimethylamine 2,4-dichlorophenoxyacetate” OR “Dimethylamine, (2,4-dichlorophenoxy)acetate” OR “Dimethylammonium 2,4-dichlorophenoxyacetate” OR “Methanamine, N-methyl-, (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine 2,4-dichlorophenoxyacetate” OR “Alkano amine salt of 2,4-D” OR “Amicide” OR “Amine-2,4-D” OR “Aminol” OR “Aminopielek 720” OR “Aminopielik 600SL” OR “Aminoprelik 39”; “Amisol” OR “Banvel 3 Liquid Herbicide” OR “Banvel-720” OR “Barber’s Weed Killer” OR “Best 4 Servis Brand Lawn Weed Killer” OR “Bladex G” OR “Blitz 64” OR “Chipman Lawn Weedkiller” OR “Co-op Premium Lawn Weed Killer” OR “D 50 (pesticide)” OR “Ded-Weed Sulv” OR “Desormone” OR “Diamond Shamrock Amine 6D” OR “Dikamin D” OR “DMA 4” OR “DMA 6” OR “DMA-2,4-D” OR “Dma-4” OR “Dow DMA-4” OR “Dow Formula 40” OR “Du Pont Lawn Weed Killer” OR “Du Pont Turf Food With Weed Killer” OR “Du Pont Weed Killer No. 2” OR “Farmco D 50” OR “Farmco D-50” OR “FS Amine 400 Weed Killer” OR “Green Cross Killex Spot Weeder Pressurized Spray” OR “Green Cross Poison Ivy Killer” OR “Herbitex” OR “Hormin” OR “Liquid Clearit Vegetation Killer” OR “Liquid Wonder Weeder” OR “Manco Kill-Weed” OR “Marquette Herbitex Plus” OR “Monosan” OR “Morselect” OR “Norkem 40t” OR “Ortho Super Weed-B-Gon Spray” OR “Phordene” OR “Reed amine 400” OR “Shirweed 500” OR “Spraygraze” OR “Spritz-Hormin” OR “Vigoro Dandelions Killer” OR “Weed-Rhap A-4D” OR “Weedar 64” OR “Weedar 96” OR “Weedkiller D” OR “Wilson’s Multi-Weeder” OR “2-Propanamine, (2,4-dichlorophenoxy)acetate”; “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2-propanamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with isopropylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropylamine salt” OR “Isopropylamine 2,4-dichlorophenoxyacetate” OR “2-Propanol, 1,1’,1”-nitrilotri-, (2,4-dichlorophenoxy)acetate (salt)” OR “2-Propanol, 1,1’,1”-nitrilotris-, (2,4-dichlorophenoxy)acetate (salt)” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotri-2-propanol” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotris(2-propanol)” OR “Triisopropanolamine 2,4-dichlorophenoxyacetate” OR “2,4-DBE” OR “2,4-DBEE” OR “2,4-Dichlorophenoxyacetic acids” OR “2-Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, butoxyethyl ester” OR “Aqua-Kleen” OR “BEE 2,4-D” OR “Bladex-B” OR “Brush killer 64” OR “Butoxy-D 3” OR “Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Butoxyethyl ester of 2,4-dichlorophenoxy acetic acid” OR “Esteron 99 Concentrate” OR “Lo-Estasol” OR “Planotox” OR “Silvaprop 1” OR “Weed-Rhap LV-4D” OR “Weedone 100 Emulsifiable” OR “Weedone 638”; “Weedone LV 4” OR “Weedone LV-6” OR “Weedone LV4” OR “2-Ethylhexyl (2,4-dichlorophenoxy)acetate” OR “2-Ethylhexyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, 1-methylethyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropyl ester” OR “Amchem Weed Killer 650” OR “Barber’s Weed Killer (Ester Formulation)” OR “Bridgeport Spot Weed Killer” OR “Crop Rider 3-34D-2” OR “Crop Rider 3.34D” OR “Esteron 44” OR “Isopropyl (2,4-dichlorophenoxy)acetate” OR “Isopropyl 2,4-dichlorophenoxyacetate” OR “Niagara Estasol” OR “Swift’s Gold Bear 44 Ester” OR “Weedone 128” OR “Acetic acid, (2,4-dichlorophenoxy)-, diethanolamine salt” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2,2’-iminobis(ethanol)”
NPIRS
01/2018 | Limited 2015-present. CASRNs searched: 94-75-7 OR 14214-89-2 OR 2307-55-3 OR 2702-72-9 OR 3766-27-6
Regulations.gov
01/2018 | CASRNs searched: 94-75-7; 14214-89-2; 2307-55-3; 2702-72-9; 3766-27-6; 5742-19-8; 2008-39-1; 5742-17-6; 18584-79-7; 1929-73-3; 1928-43-4; 94-11-1
NIH RePORTER
05/2019 | Limited to Active projects. Terms searched:; “94-75-7” OR “14214-89-2” OR “2307-55-3” OR “2702-72-9” OR “3766-27-6” OR “(2,4-Dichlorophenoxy)acetic acid” OR “(2,4-dichlorophenoxy)-Acetic acid” OR “(2,4-Dichlorophenyloxy)acetic acid” OR “2-(2,4-Dichlorophenoxy)acetic acid” OR “2-(2,4-dichlorophenoxy)-Acetic acid” OR “2,4-Dichlorophenoxyacetic acid” OR “2,4-dichloroPhenoxyacetic acid” OR “2,4-Dichlorophenoxyethanoic acid” OR “2,4-PA” OR “Ammonium 2,4-dichlorophenoxyacetate” OR “Dichlorophenoxyacetic acid” OR “Lithium 2,4-dichlorophenoxyacetate” OR “Potassium (2,4-dichlorophenoxy)acetate” OR “Potassium 2,4-dichlorophenoxyacetate” OR “Sodium (2,4-dichlorophenoxy)acetate” OR “Sodium 2,4-dichlorophenoxyacetate”; “5742-19-8” OR “2008-39-1” OR “5742-17-6” OR “18584-79-7” OR “1929-73-3” OR “1928-43-4” OR “94-11-1” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2,2’-iminobis(ethanol) (1:1)” OR “Acetic acid, (2,4-dichlorophenoxy)-, diethanolamine salt” OR “Bis(2-hydroxyethyl)ammonium 2,4-dichlorophenoxyacetate” OR “Diethanolamine 2,4-dichlorophenoxyacetate” OR “2,4-Dichlorophenoxy)acetic acid compd. with N-methylmethanamine” OR “2,4-Dichlorophenoxy)acetic acid dimethylamine salt” OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, cmpd with N-methylmethanamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with dimethylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with N-methylmethanamine” OR “Dimethylamine 2,4-dichlorophenoxyacetate” OR “Dimethylamine, (2,4-dichlorophenoxy)acetate” OR “Dimethylammonium 2,4-dichlorophenoxyacetate” OR “Methanamine, N-methyl-, (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine (2,4-dichlorophenoxy)acetate” OR “N-Methylmethanamine 2,4-dichlorophenoxyacetate” OR “2-Propanamine, (2,4-dichlorophenoxy)acetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 2-propanamine”; “Acetic acid, (2,4-dichlorophenoxy)-, compd. with isopropylamine” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropylamine salt” OR “Isopropylamine 2,4-dichlorophenoxyacetate” OR “2-Propanol, 1,1’,1”-nitrilotri-, (2,4-dichlorophenoxy)acetate (salt)” OR “2-Propanol, 1,1’,1”-nitrilotris-, (2,4-dichlorophenoxy)acetate (salt)” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotri-2-propanol” OR “Acetic acid, (2,4-dichlorophenoxy)-, compd. with 1,1’,1”-nitrilotris(2-propanol)” OR “Triisopropanolamine 2,4-dichlorophenoxyacetate” OR “2,4-DBE” OR “2,4-DBEE” OR “2,4-Dichlorophenoxyacetic acids” OR “2-Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-butoxyethyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, butoxyethyl ester” OR “Butoxyethyl 2,4-dichlorophenoxyacetate” OR “Butoxyethyl ester of 2,4-dichlorophenoxy acetic acid” OR “2-Ethylhexyl (2,4-dichlorophenoxy)acetate” OR “2-Ethylhexyl 2,4-dichlorophenoxyacetate” OR “Acetic acid, (2,4-dichlorophenoxy)-, 2-ethylhexyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, 1-methylethyl ester” OR “Acetic acid, (2,4-dichlorophenoxy)-, isopropyl ester” OR “Isopropyl (2,4-dichlorophenoxy)acetate” OR “Isopropyl 2,4-dichlorophenoxyacetate”
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2018 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 794
- Number of records identified from other strategies: 36
- Total number of records to undergo literature screening: 830

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on 2,4-D:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 830
- Number of studies considered relevant and moved to the next step: 57

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 57
- Number of studies cited in the pre-public draft of the toxicological profile: 361
- Total number of studies cited in the profile: 399

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 January 2018 Literature Search Results and Screen for 2,4-D