# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: An acute-duration inhalation MRL was not derived for 2,4-D.

Rationale for Not Deriving an MRL: No acute-duration inhalation data were available for review.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: An intermediate-duration inhalation MRL was not derived for 2,4-D.

Rationale for Not Deriving an MRL: Only one inhalation study in animals was available for review. In that study, male and female rats were exposed nose-only 6 hours/day, 5 days/week for 28 days to 2,4-D dusts in target concentrations of 0, 50, 100, 300, and 1,000 mg/m^3^ (EPA 2008). After termination of exposure, controls and rats from the highest exposure concentration group were kept for a 4-week recovery period to assess reversibility of the effects. A significant reduction in reticulocytes occurred in males and females at 2,4-D exposure concentrations ≥300 mg/m^3^ and a significant increase in serum alkaline phosphatase was reported in females at ≥300 mg/m^3^. Histopathologic examination of a comprehensive set of organs and tissues revealed no sign of 2,4-D exposure-related systemic effects. The most salient effect was the occurrence of squamous/squamoid epithelial metaplasia with hyperkeratosis in the larynx of all exposed groups, with increasing severity as the exposure concentration increased. The lesions persisted during the recovery period, but with reduced severity. Therefore, the exposure concentration of 50 mg/m^3^ represents the study LOAEL, a portal-of-entry LOAEL. Although this is a well-conducted study that examined a comprehensive number of end points, the database is insufficient for MRL derivation. It would be important to determine a NOAEL for the portal-of-entry effects.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: A chronic-duration inhalation MRL was not derived for 2,4-D

Rationale for Not Deriving an MRL: No chronic-duration inhalation data were available for review.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: An acute-duration oral MRL was not derived for 2,4-D.

Rationale for Not Deriving an MRL: No adequate acute-duration human data were located. Information regarding health effects in humans following acute-duration exposure to 2,4-D is limited to case reports of intentional or accidental ingestion of herbicide formulations containing 2,4-D. Effects that have been reported following oral exposure to high amounts of 2,4-D include tachypnea, tachycardia, vomiting, leukocytosis, liver and kidney congestion in fatal cases, metabolic acidosis, and death (Dudley et al. 1972; Durakovic et al. 1992; Keller et al. 1994; Nielsen et al. 1965; Smith and Lewis 1987). While some of these studies provided estimates of amounts of 2,4-D ingested, the reported effects represent the result of exposure to a chemical mixture consisting of 2,4-D and other substances present in the commercial formulations (i.e., solvents, other herbicides), which is the exposure that most humans experience. Yet, the common exposure reported across studies was to 2,4-D. In two studies designed to evaluate the pharmacokinetics of 2,4-D in volunteers, administration of 5 mg 2,4-D/kg once in a gelatin capsule resulted in no ill effects during 144–168 hours post-dosing (Kohli et al. 1974; Sauerhoff et al. 1977). The information available in humans is inadequate for MRL derivation.

Two animal studies defined LOAELs of 50 mg/kg/day. In one of these studies, doses of 50 mg/kg/day (lowest dose tested) induced significant weight loss in pregnant Wistar rats when administered by gavage in water on GDs 6–15 (Fofana et al. 2000). It is not totally clear, however, whether the investigators meant that the final weight was lower than the starting weight or whether treated rats just gained less weight than control rats. In another developmental study, administration of 2,4-D at 50 mg/kg/day by gavage in corn oil to pregnant Sprague-Dawley rats, also on GDs 6–15, did not affect maternal weight (terminal weight similar in treated and controls), but induced a statistically significant reduction in fetal weight (approximately 7%) measured on GD 20 and increased the incidence of some soft-tissue anomalies and skeletal malformations; the NOAEL was 25 mg/kg/day (Schwetz et al. 1971). Long-term oral studies suggest that the kidney is a target for 2,4-D toxicity; however, only one acute-duration study conducted microscopic examinations of the kidneys. The paucity of information regarding the effects of acute-duration oral exposure to 2,4-D in experimental animals precludes deriving an acute-duration oral MRL for 2,4-D.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.2 mg/kg/day
Critical Effect: | Increased kidney weight, histopathologic kidney lesions
Reference: | Marty et al. 2013
Point of Departure: | 16.6 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
LSE Graph Key: | 33
Species: | Rat

MRL Summary: An MRL of 0.2 mg/kg/day has been derived for intermediate-duration oral exposure to 2,4-D based on a NOAEL of 16.6 mg/kg/day and a LOAEL of 45.3 mg/kg/day for increased kidney weight and slight proximal tubule degeneration in the kidney of male Sprague-Dawley rats receiving 2,4-D from food for up to 11 weeks (Marty et al. 2013).

Selection of the Critical Effect: No human data were located. Available animal data identify the kidney and developmental endpoints as most sensitive to 2,4-D toxicity. Available results from intermediate-duration oral treatment of dogs were not considered an appropriate basis for MRL derivation because dogs appear to be more sensitive than rodents or humans due to a significantly lower capacity to eliminate 2,4-D via the kidneys (Timchalk 2004). Table A-1 summarizes study results for renal effects and for developmental effects considered potential points of departure for deriving an intermediate-duration oral MRL for 2,4-D.

Table A-1 Summary of Potential Candidate Critical Effects for Deriving an Intermediate-Duration Oral MRL for 2,4-D

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Renal effects
F344 rat | 13 weeks (F) | 1 | 5 | Increased homogeneity and altered tinctorial properties in cytoplasm; fine vacuolization of cytoplasm in renal cortex | EPA 1984
B6C3F1 mouse | 13 weeks (F) | 5 | 15 | M, F: Increased homogeneity, altered tinctorial properties in cytoplasm or renal cortex; M: decreased vacuolization in renal cortex | EPA 1984
B6C3F1 mouse | 52 weeks (F) | 1 M; 45 F | 15 M | Increased cytoplasmic homogeneity of renal tubular epithelium due to reduction of cytoplasmic vacuoles | EPA 1987a
F344 rat | 40 weeks (F) | 5 M | 20 M | Increased incidence and severity of fine vacuolization in cytoplasm of renal cortex | EPA 1987b
F344 rat | 52 weeks (F) | 15 F | 45 F | F: Increased incidence and severity of fine vacuolization in cytoplasm of renal cortex | EPA 1985
Crl:CD(SD) rat | M: 11–13 weeks; F: 10–12 weeks (F) | 16.6 M; 45.2^a^ F | 45.3 M | Increased relative kidney weight, increased incidence of multifocal slight degeneration of proximal convoluted tubules in outer stripe of outer zone of medulla | Marty et al. 2013
Crl:CD(SD) rat | PPDs 21–70^b^ (F) | 28.4 M; 28.8 F | 76.6 M; 57.9 F | F1 parental males and females: kidney lesions similar to those of P1 males | Marty et al. 2013
F344 rat | 13 weeks (F) | 15 | 60 | M: Increased epithelial cytoplasmic homogeneity, multifocal slight degeneration in descending proximal tubules; F: Increased cytoplasmic vacuolization in proximal convoluted tubules | Gorzinski et al. 1987
B6C3F1 mouse | 12 months (F) | 5 M | 62.5 M | 5% increased kidney weight; degeneration/regeneration in descending limb of proximal tubules; vacuolation of proximal tubules | Charles et al. 1996a; EPA 1996b
F344 rat | 52 weeks (F) | 5 | 75 | Degeneration of proximal convoluted tubules | Charles et al. 1996a; EPA 1996a
Crl:CD(SD) rat | M: 71 days; F: 96 days (F) | 50 M | 75 M | Slight multifocal degeneration of proximal convoluted tubules in outer stripe of outer zone of medulla of males | Saghir et al. 2013a
F344 rat | 13 weeks (F) | 15 | 100 | 21 and 12% increased relative kidney weight in males and females, respectively | Charles et al. 1996b
Developmental effects
Crl:CD(SD) rat | 42 days (GD 1–LD 21 (F) | 24.7 F | 49.4 F | 9% depressed PPD 22 F1a male pup body weight (based on estimated TWA parental female dose for GD 0–LD 14) | Marty et al. 2013
Crl:CD(SD) rat | M: 80 days; F: 95 days (F) | 25 | 50 | 13–23% depressed pup weight during PPDs 14–21 | Saghir et al. 2013a, 2013b
F344 rat | 40 weeks (F) | 32 | 110 | 24% depressed PPD 21 pup body weight | EPA 1986

a The P1 female dose is a TWA dose calculated from reported dose estimates for three separate time periods (29 days premating, 21 days of gestation, and the first 14 days of lactation).

b Rats had been exposed via their mothers during gestation and lactation as well.

F = female(s); (F) = food; GD = gestation day; LD = lactation day; LOAEL = lowest observed adverse effect level; M = male(s); NOAEL = no-observed-adverse-effect level; PPD = postparturition day; TWA = time-weighted average

Selection of the Principal Study: Available Data Evaluation Records (DERs) from early studies submitted to EPA (EPA 1984, 1985, 1987a, 1987b) provide inadequate descriptions of the kidney lesions reported. Thus, the degenerative nature of the described lesions is in question. Therefore, these studies were not considered as candidate principal studies for deriving an intermediate-duration oral MRL for 2,4-D.

Three studies provide corroborative evidence of degenerative changes in renal proximal tubules within the outer stripe of the outer zone of the medulla of rats (Gorzinski et al. 1987; Marty et al. 2013; Saghir et al. 2013a). Each of these studies described similar histologic changes that included shrinking, crowding and basophilic staining of epithelial cells, and basement membrane thickening.

- Marty et al. (2013, and as more fully described in MRID4792101): “This degenerative lesion involving the proximal convoluted tubules in the outer strip of the outer zone of the medulla, was multifocal in distribution and slight in degree. This lesion was primarily characterized by tubular epithelial cells, which were basophilic staining and had nuclei that were crowded together due to a decrease in the amount of cytoplasm (eosinophilic staining). Pyknotic nuclei were also occasionally noted in these tubules. Remaining portions of these tubular profiles appeared normal. Affected tubules also had focally thickened basement membranes, adjacent interstitial fibrous connective tissue proliferation and a mononuclear inflammatory cell infiltrate”.
- Saghir et al. (2013a, study submitted to EPA as MRID47417901): “This was a degenerative multifocal lesion involving the proximal convoluted tubules in the outer strip of the outer zone of the medulla and was very slight or slight in degree of severity. This lesion was primarily characterized by tubular epithelial cells, which were basophilic staining and had nuclei that were crowded together due to a decrease in the amount of cytoplasm (eosinophilic staining). Pyknotic nuclei were also occasionally noted in these tubules. Remaining portions of these tubular profiles appeared normal. Affected tubules also had focally thickened basement membranes, adjacent interstitial fibrous connective tissue proliferation and a mononuclear inflammatory cell infiltrate”.
- Gorzinski et al. (1987): “…multifocal degeneration in the descending part of the proximal tubules…basophilic epithelial cells that were crowded because of decreased cytoplasm…[underlined: accompanied with] thickened basement membranes and interstitial fibrosis”.

None of the above studies found evidence of cell death or tubule destruction (e.g., apoptosis, necrosis), even at the highest dose, and no studies found evidence of renal functional impairment. Therefore, the histological changes observed can be considered to be minimally severe (pre-clinical) indications of degenerative changes that might become more severe at higher doses and/or longer exposure durations.

Two-year oral studies in rats (Charles et al. 1996a; EPA 1996b) and mice (Charles et al. 1996a; EPA 1996a) included histopathological evaluations at 1-year interim sacrifice. The rat study identified a NOAEL of 5 mg/kg/day and a LOAEL of 75 mg/kg/day for degeneration in proximal tubules. The mouse study identified a NOAEL of 5 mg/kg/day and a LOAEL of 62.5 mg/kg/day for degeneration/regeneration in descending limb of proximal tubules in the male mice. There was no mention of basement membrane thickening in the publicly-available summaries of these studies or the unpublished MRID studies. Therefore, these studies were not considered as candidate principal studies for MRL derivation.

Kidney results for male rats from the studies of Gorzinski et al. (1987), Saghir et al. (2013a), and Marty et al. (2013) are summarized in Tables A-2, A-3, and A-4, respectively. Gorzinski et al. (1987) identified a NOAEL of 15 mg/kg/day and La OAEL of 60 mg/kg/day for multifocal degeneration of the descending proximal tubule. The severity of the lesions was graded as slight at 60 mg/kg/day and moderate at ≥100 mg/kg/day. The Saghir et al. (2013a) and Marty et al. (2013) studies reported very slight multifocal degeneration of the convoluted tubules in male rats at low dose levels. The very slight generation was not considered adverse because it was not associated with alterations in kidney weight or evidence of renal impairment. Additionally, a high incidence (9/10) of very slight degeneration was observed in the control group of the Marty et al. (2013) study. The slight degeneration observed at higher doses was considered adverse. The NOAEL and LOAEL values were 50 and 75 mg/kg/day, respectively, in the Saghir et al. (2013a) study and 16.6 and 45.3 mg/kg/day, respectively, in the Marty et al. (2013) study.

Table A-2 Selected Kidney Results from Male F344 Rats Receiving 2,4-D from the Diet for 11 Weeks

Reported 2,4-D dose (mg/kg/day) | 0 | 15 | 60 | 100 | 150
Degeneration descending proximal tubule
Slight multifocal degeneration | 0/10 | 2/10 | 8/10^a^ | 1/10 | 0/10
Moderate multifocal degeneration | 0/10 | 0/10 | 2/10 | 9/10^a^ | 10/10^a^

a Statistically different from control mean by Fischer’s exact test (p<0.01) performed by ATSDR.

Source: Gorzinski et al. 1987

Table A-3 Selected Kidney Results from Male Crl:CD(SD) Rats Receiving 2,4-D from the Diet for 11 Weeks

Dietary concentration (ppm) | 0 | 100 | 400 | 1,000/800 | 2,000/1,200 | 1,600
Estimated dose (mg/kg/day)^a^ | 0 | 6 | 25 | 50 | 75 | 100
Kidney weight (g/100 g body weight) | 0.68 | 0.72 | 0.71 | 0.74 | 0.75 | 0.81^b^
Degeneration proximal convoluted tubule
Very slight multifocal degeneration | 1/10 | 1/10 | 6/10^c^ | 8/10^c^ | 4/10^d^ | 7/10^c^
Slight multifocal degeneration | 0/10 | 0/10 | 0/10 | 0/10 | 4/10^c^ | 1/10

a Estimated dose for prebreeding period only.

b Statistically different from control mean by Dunnett’s test (α=0.05).

c Statistically different from control mean by Fischer’s exact test (p<0.01) performed by ATSDR.

d Statistically different from control mean by Fischer’s exact test (p<0.05) performed by ATSDR.

Source: Saghir et al. 2013a

Table A-4 Selected Kidney Results from Male Crl:CD(SD) Rats Receiving Technical Grade 2,4-D from the Diet up to 13 Weeks

Dietary concentration (ppm) | 0 | 100 | 300 | 800
Estimated dose (mg/kg/day) | 0 | 5.51 | 16.6 | 45.3
Degeneration proximal convoluted tubule
Very slight multifocal degeneration | 9/10 | 4/10 | 6/10 | 3/11
Slight multifocal degeneration | 1/10 | 0/10 | 1/10 | 8/11^a^
Kidney weight (g/100 g body weight) | 0.662 | 0.686 | 0.685 | 0.734^b^

a Statistically different from control mean by Fisher’s exact test (p<0.01)

b Statistically different from control mean by Dunnett’s test (α=0.05).

Source: Marty et al. 2013

Collectively, the studies of Gorzinski et al. (1987), Marty et al. (2013), and Saghir et al. (2013a) support a LOAEL range of 45–75 mg/kg/day for slight degenerative changes in the renal proximal tubule, and a NOAEL range of 6–16.6 mg/kg/day. Among the three studies providing adequate description of degenerative changes in the renal proximal tubule (Gorzinski et al. 1987; Marty et al. 2013; Saghir et al. 2013a), the study of Marty et al. (2013) identified the lowest LOAEL (45.3 mg/kg/day) for increased kidney weight and slight degeneration of the proximal tubule in the parental male rats administered 2,4-D in the diet for up to 13 weeks; the corresponding NOAEL for this effect was 16.6 mg/kg/day. Therefore, the Marty et al. (2013) study was selected as the principal study for deriving an intermediate-duration oral MRL for 2,4-D.

Summary of the Principal Study:

Marty MS, Neal BH, Zablotny CL, . 2013. An F1-extended one-generation reproductive toxicity study in Crl:CD(SD) rats with 2,4-dichlorophenoxyacetic acid. Toxicol Sci 136(2):527–547. 10.1093/toxsci/kft213.24072463

In the principal study, male Sprague-Dawley rats (27/group) were fed a diet containing 0, 100, 300, or 800 ppm 2,4-D (97.85% pure) for 4 weeks premating, up to 2 weeks of mating, and up to 7 weeks postmating. This diet provided estimated 2,4-D doses of 0, 5.5, 16.6, and 45.3 mg/kg/day, respectively, to the parental males. Female rats (27/group) were fed a diet containing 0, 100, 300, or 600 ppm 2,4-D for 29 days premating and through gestation (21 days) and lactation (21 days). Estimated 2,4-D doses to the parental females in the 0, 100, 300, and 800 ppm dietary groups were:

- 0, 6.97, 20.6, and 40.2 mg/kg/day during premating;
- 0, 7.37, 21.9, and 43.7 mg/kg/day for GDs 0–20;
- 0, 10.7, 32.4, and 64.5 g/kg/day for LDs 1–7; and
- 0, 8.4, 25.5, and 51.5 mg/kg/day for LDs 7–14.

The P1 generation was evaluated for systemic toxicity as well as reproductive toxicity.

Body weight was reduced in high-dose parental females during lactation, but no data were shown. Exposure to 2,4-D increased absolute and relative kidney weight (11–13%) in high-dose parental males and increased relative kidney weight (11%) in one set of F1 high-dose females. Renal lesions consisting of very slight to slight degeneration of the proximal convoluted tubules in the outer zone of the medulla were seen in high-dose parental males and in two sets of adult F1 females. There were no treatment-related lesions in other tissues (tissues not specified in paper). Renal lesions appeared more severe in males than in females. Nonsignificant decreased T4 and T3 and increased TSH were seen in high-dose satellite females on GD 17. Three out of 12 females had histological alterations consisting of smaller thyroid follicles with small vacuoles in the colloid suggesting colloid resorption. There were no adverse pathological alterations or changes in LD 21 dams, suggesting that the changes were transient and were therefore considered adaptive, although the changes were considered exposure-related.

The kidney effects in the parental male rats (increased incidence of slight degeneration in proximal tubules and increased kidney weight at 45.3 mg/kg/day) in the study of Marty et al. (2013) represent the most sensitive endpoint of intermediate-duration oral exposure to 2,4-D.

Selection of the Point of Departure for the MRL: A benchmark dose (BMD) approach was initially considered to derive an intermediate-duration oral MRL for 2,4-D based on incidences of kidney lesions (slight multifocal degeneration in the proximal convoluted tubule) in the male rats of Marty et al. (2013). However, as shown in Table A-4, an increased incidence of slight degeneration in the proximal tubules of the male rats was only observed in the high-dose group (incidence of 8/11 at 45.3 mg/kg/day versus 1/10, 0/10, and 1/10 for controls, 5.51, and 16.6 mg/kg/day groups, respectively). A dataset exhibiting a response only at the highest dose level would likely provide limited information regarding the shape of a dose-response curve. Therefore, the NOAEL of 16.6 mg/kg/day was considered the most appropriate potential point of departure for the male rat kidney lesion data from Marty et al. (2013).

Relative kidney weight in the male rats of Marty et al. (2013) was amenable to BMD analysis using the mean (and standard deviation) kidney weight data reported in an unpublished version of this study (MRID4792101). All continuous variable models in the benchmark dose software (BMDS) Version 3.1 were fit to the mean relative kidney weight data using a benchmark response (BMR) of one standard deviation from control in the absence of a rationale for using an alternative BMR.

The resulting potential point of departure (BMDL_1SD_ of 34.12 mg/kg/day from the best-fitting model) was higher than the point of departure using a NOAEL/LOAEL approach (NOAEL of 16.6 mg/kg/day). Therefore, the NOAEL/LOAEL approach was taken to derive an intermediate-duration oral MRL.

Calculations

Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL of 16.6 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ uncertainty factors MRL = 16.6 mg/kg/day ÷ ( 10 × 10 ) = 0.2 mg/kg/day .

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Kidney lesions (degeneration of the descending portion of proximal convoluted tubules) were reported in male and female rats receiving 2,4-D from food at 75 mg/kg/day for 12 months (interim sacrifice in a 2-year study); the NOAEL was 5 mg/kg/day (Charles et al. 1996a; EPA 1996a). Both 12-month interim and 2-year terminal sacrifices of male B6C3F1 mice revealed degenerative kidney lesions in the descending portion of proximal convoluted at a 2,4-D dose level of 62.5 mg/kg/day (Charles et al. 1996a; EPA 1996b). The NOAEL in the mouse study was 5 mg/kg/day.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-D
CAS Numbers: | 94-75-7
Date: | July 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.2 mg/kg/day
Critical Effect: | Proximal tubule degeneration/regeneration in kidney
Reference: | Charles et al. 1996a; EPA 1996b
Point of Departure: | 16.66 mg/kg/day (BMDL_10_)
Uncertainty Factor: | 100
LSE Graph Key: | 59
Species: | Mouse

MRL Summary: An MRL of 0.2 mg/kg/day has been derived for chronic-duration oral exposure to 2,4-D based on a BMDL_10_ of 16.66 mg/kg/day for proximal tubule degeneration/regeneration in the kidney of male B6C3F1 mice receiving 2,4-D from food for up to 2 years (Charles et al. 1996a; EPA 1996b).

Selection of the Critical Effect: Table A-5 summarizes the potential candidate critical effects for deriving a chronic-duration oral MRL for 2,4-D.

Table A-5 Summary of Potential Candidate Critical Effects for Deriving a Chronic-Duration Oral MRL for 2,4-D

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
F344 rat | 2 years (F) | 5 | 75 | 19% depressed weight gain in females | Charles et al. 1996a; EPA 1996a
Hematological effects
F344 rat | 2 years (F) | 5 | 75 | M: decreased platelets; F: decreases in platelets, RBC count, hematocrit | Charles et al. 1996a; EPA 1996a
Renal effects
B6C3F1 mouse | 2 years (F) | 5 M; 5 F | 62.5 M; 150 F | Proximal tubule degeneration/regeneration | Charles et al. 1996a; EPA 1996b
Endocrine effects
F344 rat | 2 years (F) | 5 | 75 | M, F: decreased serum T4; F: increased thyroid weight | Charles et al. 1996a; EPA 1996b

(F) = food; F = female(s); LOAEL = lowest observed adverse effect level; M = male(s); NOAEL = no-observed-adverse-effect level; RBC = red blood cell; T4 = thyroxine

Selection of the Principal Study: No adequate human data were located. Chronic-duration oral studies in rats (Charles et al. 1996a; EPA 1996a; Hansen et al. 1971), mice (Charles et al. 1996a; EPA 1987a, 1996b), and dogs (Hansen et al. 1971) were available for review. In the dog study (Hansen et al. 1971), no adverse effects were observed at the highest 2,4-D dose level tested (10 mg/kg/day). Furthermore, as previously stated, dogs appear to be more sensitive to 2,4-D toxicity than other species (including humans) due to a significantly lower capacity to eliminate 2,4-D via the kidneys (Timchalk 2004). Therefore, the dog study was not considered as a potential principal study for deriving a chronic-duration oral MRL for 2,4-D.

A 2-year bioassay in F-344 rats defined an overall NOAEL of 5 mg 2,4-D/kg/day for organs and tissue histopathology and hematological and clinical chemistry parameters (Charles et al. 1996a; EPA 1996a). An oral dose level of 75 mg/kg/day resulted in decreased platelet and erythrocyte counts and hematocrit in female rats (data not shown), increased serum ALT in male rats, and decreased serum T4 in both sexes. Histological alterations were noted at 150 mg/kg/day and consisted of a nonsignificant increase in parafollicular cell nodular hyperplasia in the thyroid from females and minimal panlobular tinctorial properties in the liver from males and females. No clear treatment-related histological alterations were observed in the kidneys at 2,4-D doses of 5, 75, or 150 mg/kg/day. An earlier study did not report treatment-related alterations in organs and tissues from Osborne-Mendel rats receiving 2,4-D from food for 2 years at approximately 92 mg/kg/day (Hansen et al. 1971).

In a 2-year mouse study submitted to EPA, male B6C3F1 mice receiving 2,4-D from food for 2 years at 15 mg/kg/day exhibited significantly increased incidence of cytoplasmic homogeneity in the renal tubular epithelium; this was attributed to a reduction of cytoplasmic vacuoles normally present in the cytoplasm of epithelial cells. No significant increase was seen at 1 mg/kg/day. The available DER from the study (EPA 1987a) provides an inadequate description of the kidney lesions reported. Thus, the degenerative nature of the described lesions is in question. Therefore, this study was not considered as a candidate for deriving a chronic-duration oral MRL for 2,4-D.

In another 2-year mouse study (Charles et al. 1996a; EPA 1996b), a significant increase in minimal degeneration with regeneration of the descending portion of the proximal tubules was reported for male B6C3F1 mice receiving 2,4-D from food at ≥62.5 mg/kg/day; the NOAEL was 5 mg/kg/day. Reduced vacuolization of the cytoplasm in tubular cells of the male mice dosed at ≥62.5 mg/kg/day was noted as well. Because of the unclear biological significance of the reduced vacuolization of the cytoplasm in tubular cells, the degeneration/regeneration change in the proximal tubule of the male mice represents a more toxicologically relevant endpoint for MRL derivation. No other treatment-related histological alterations in organs or tissues or in hematology tests were reported in mice.

The 2-year mouse study (Charles et al. 1996a; EPA 1996b) was selected as the principal study for deriving a chronic-duration oral MRL for 2,4-D because it identified the lowest reliable LOAEL for kidney effects that represent the most sensitive target of 2,4-D toxicity.

Summary of the Principal Study:

Charles JM, Bond DM, Jeffries TK, . 1996a. Chronic dietary toxicity/oncogenicity studies on 2,4-dichlorophenoxyacetic acid in rodents. Fundam Appl Toxicol 33(2):166–172.8921335

EPA. 1996b. Data Evaluation Record. Carcinogenicity study – mice. 2,4-Dichlorophenoxyacetic acid (2,4-D) [MRIDs evaluated: 43879801 & 43597201]

Groups of B6C3F1 mice (60/sex/group) were fed a diet for 2 years that provided 2,4-D at 0, 5, 62.5, and 125 mg/kg/day for males and 0, 5, 150, and 300 mg/kg/day for females (Charles et al. 1996a; EPA 1996b). Ten mice per group were killed at 1 year for examination. Endpoints monitored included overt toxicity, morbidity, and lethality at least twice weekly. Body weight, clinical signs, and food consumption were determined weekly for the first 13 weeks and monthly thereafter. Ophthalmoscopic examination was performed at the beginning and at the end of the study. Hematology testing was conducted during weeks 52, 78, and 104. All survivors were subjected to necropsy after 52 or 104 weeks of treatment. Major organ weights were recorded; all major organs and tissues were examined microscopically.

Dosing with 2,4-D did not significantly affect survival rate. There were no treatment-related changes in clinical appearance or behavior. Body weight gain was not significantly affected by dosing with 2,4-D. Results from hematological tests were unremarkable. Ophthalmology tests did not show treatment-related alterations. Significant changes in organ weights were limited to an increase in relative kidney weight in males and females at 125 mg/kg/day. Treatment-related histological alterations were restricted to the kidneys and consisted of a significant increase in the incidence of degeneration/regeneration in the descending limb of the proximal tubule of the kidneys in males and females at 62.5 and 125 mg/kg/day and increased incidence of vacuolization of the proximal tubule in males at 62.5 and 125 mg/kg/day.

Selection of the Point of Departure for the MRL: The incidence data for degeneration with regeneration of the descending portion of the proximal tubules in the male mice (Table A-6) were analyzed using all available dichotomous models in the EPA BMDS (version 3.1), the extra risk option, and a BMR of 10% change from controls.

Table A-6 Incidence of Degeneration/Regeneration in the Descending Limb of the Proximal Tubules of Male B6C3F1 Mice Administered 2,4-D in the Food for 2 Years

Dose (mg/kg/day) | Mice/group | Incidence
0 | 50 | 0
5 | 50 | 0
62.5 | 50 | 25^a^
125 | 50 | 48^a^

a p≤0.05.

Sources: Charles et al. 1996a; EPA 1996b

Adequate model fit was judged by three criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the point of departure when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. As shown in Table A-7, all models except the Multistage (1-degree) and Dichotomous Hill models provided an adequate fit to the dataset.

Table A-7 Model Predictions for Incidence of Degeneration/Regeneration in the Descending Limb of the Proximal Tubules of Male Mice Administered 2,4-D in the Food for 2 Years

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/d) | BMDL_10_ (mg/kg/d)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/d) | BMDL_10_ (mg/kg/d)
Gamma^c^ | 1 | 0.0014 | 0.97 | −0.0368 | 0.0035 | −0.0368 | 92.112 | 33.25 | 20.70
LogLogistic | 1 | 0.0005 | 0.98 | −0.0216 | 0.0006 | −0.0216 | 92.110 | 38.71 | 27.32
Multistage (3-degree)^d^ | 1 | 0.1893 | 0.66 | −0.423 | 0.0859 | −0.423 | 92.477 | 26.11 | 16.00
Multistage (2-degree) ^d^ ^,^ ^e^ | 3 | 0.4844 | 0.92 | −0.487 | −0.323 | −0.487 | 88.841 | 23.59 | 16.66
Multistage (1-degree)^d^ | 3 | 11.342 | 0.01
Weibull^c^ | 1 | 0.1275 | 0.72 | −0.001 | 0.047 | 0.047 | 92.345 | 27.53 | 17.95
Dichotomous Hill^f^ | 0 | 0.0005 | ND
Logistic | 2 | 3.7024 | 0.16 | −0.8699 | 0.7077 | −1.382 | 94.514 | 35.19 | 27.68
LogProbit^g^ | 1 | 1.5×10^−6^ | 1.00 | −0.0009 | 8.9×10^−6^ | 8.9×10^−6^ | 92.109 | 37.63 | 26.33
Probit | 2 | 3.1532 | 0.21 | −0.8026 | 0.9576 | −1.093 | 94.007 | 32.63 | 25.34

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Slope restricted to ≥1.

d Power restricted to ≥1.

e Among models providing adequate fit to the data, BMDL_10_ values varied by <3-fold; therefore, the model with the lowest AIC was selected as the best-fitting model (2-degree Multistage).

f Invalid degrees of freedom and χ^2^ values.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND = not determined (degrees of freedom = 0; model saturated; goodness-of-fit not calculated)

The model providing the best fit (lowest AIC) is the Multistage (2-degree) model, which defined a BMD_10_ of 23.59 mg 2,4-D/kg/day and a BMDL_10_ of 16.66 mg 2,4-D/kg/day. The fit of the multistage (2-degree) model is presented in Figure A-1.

Figure A-1 Fit of Multistage (2-Degree) Model for Degeneration/Regeneration in Descending Limb of Proximal Tubules of Male B6C3F1 Mice Administered 2,4-D in the Food for 2 Years

Calculations

Intermittent Exposure: Not applicable

Uncertainty Factor: The BMDL_10_ of 16.66 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_10_ ÷ uncertainty factors MRL = 16.66 mg/kg/day ÷ ( 10 × 10 ) = 0.2 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Kidney lesions (degeneration of the descending portion of proximal convoluted tubules) were reported in male and female rats receiving 2,4-D from food at 75 mg/kg/day for 12 months (interim sacrifice in a 2-year study); the NOAEL was 5 mg/kg/day (Charles et al. 1996a; EPA 1996a). Both 12-month interim and 2-year terminal sacrifice among male and female B6C3F1 mice revealed kidney lesions in the descending portion of proximal convoluted tubules (degeneration in males and hypercellularity in females) at a dose level of 62.5 and 150 mg/kg/day for males and females, respectively, at both 12-month interim and 2-year terminal sacrifice (Charles et al. 1996a; EPA 1996b). The NOAEL in the mouse study was 5 mg/kg/day for both sexes. Increased relative kidney weight and increased incidence of slight degeneration of proximal tubules in outer zone of medulla were reported among male Sprague-Dawley rats receiving 2,4-D from food for up to 12 weeks at 45.3 mg/kg/day; the corresponding NOAEL was 16.6 mg/kg/day (Marty et al. 2013).

Agency Contacts (Chemical Managers): Obaid Faroon